# References

1 American Cancer Society. Cancer Facts & Figures 2011. Atlanta, GA. 2011. http://www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-029771.pdf.
2 Hanahan D, Weinberg RA. The hallmarks of cancer. Cell. Jan. 7. 2000;100(1):57-70. [pmid: 10647931].
3 National Cancer Institute. Metastatic Cancer. Rockville, MD. National Cancer Institute. 2011. http://www.cancer.gov/cancertopics/factsheet/Sites-Types/metastatic. Accessed December 12, 2011.
4 Naresh K. Do metastatic tumours from an unknown primary reflect angiogenic incompetence of the tumour at the primary site? - a hypothesis. Med Hypotheses. 2002;59:357-360. [pmid: 12208170].
5 Van’t Veer La WB. Road map to metastasis. Nat Med. 2002;9:999-1000.
6 Tong KB, Hubert HB, Santry B, et al. Incidence, costs of care and survival of medicare beneficiaries diagnosed with carcinoma of unknown primary origin. Annual meeting of the American Society of Clinical Oncology. 2006 June 2–6. Atlanta, GA.
7 Greco FA, Oien K, Erlander M, et al. Cancer of unknown primary: progress in the search for improved and rapid diagnosis leading toward superior patient outcomes. Ann Oncol. 2011. Jun. 27. [pmid: 21709138].
8 National Comprehensive Cancer Network. NCCNTM Guidelines Version 1.2012 Occult Primary. 2011.
9 Varadhachary GR, Abbruzzese JL, Lenzi R. Diagnostic strategies for unknown primary cancer. Cancer. May. 1. 2004;100(9):1776-1785. [pmid: 15112256].
10 Anderson GG, Weiss LM. Determining tissue of origin for metastatic cancers: meta-analysis and literature review of immunohistochemistry performance. Appl Immunohistochem Mol Morphol. Jan. 2010;18(1):3-8. [pmid: 19550296].
11 Dennis JL, Hvidsten TR, Wit EC, et al. Markers of adenocarcinoma characteristic of the site of origin: development of a diagnostic algorithm. Clin Cancer Res. May. 15. 2005;11(10):3766-3772. [pmid: 15897574].
12 Pelosi E, Pennone M, Deandreis D, et al. Role of whole body positron emission tomography/computed tomography scan with 18F-fluorodeoxyglucose in patients with biopsy proven tumor metastases from unknown primary site. Q J Nucl Med Mol Imaging. Mar. 2006;50(1):15-22. [pmid: 16557200].
13 Nanni C, Rubello D, Castellucci P, et al. Role of 18F-FDG PET-CT imaging for the detection of an unknown primary tumor: preliminary results in 21 patients. Eur J Nucl Med Mol Imaging. 2005;32:589-592. [pmid: 15726356].
14 Pantou D, Tsarouha H, Papadopoulou A, et al. Cytogenetic profile of unknown primary tumors: clues for their pathogenesis and clinical management. Neoplasia. Jan-Feb. 2003;5(1):23-31. [pmid: 12659667].
15 Ramaswamy S, Tamayo P, Rifkin R, et al. Multiclass cancer diagnosis using tumor gene expression signatures. Proc Natl Acad Sci U S A. Dec. 18. 2001;98(26):15149-15154. [pmid: 11742071].
16 Greco FA, Erlander MG. Molecular classification of cancers of unknown primary site. Mol Diagn Ther. Dec. 1. 2009;13(6):367-373. [pmid: 19925034].
17 Methods Guide for Medical Test Reviews. Agency for Healthcare Research and Quality. 2010. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=454.
18 Simon R, Radmacher MD, Dobbin K, et al. Pitfalls in the use of DNA microarray data for diagnostic and prognostic classification. J Natl Cancer Inst. Jan. 1. 2003;95(1):14-18. [pmid: 12509396].
19 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
20 Viswanathan M, Berkman ND. Development of the RTI Item Bank on Risk of Bias and Precision of Observational Studies. Rockville (MD). 2011.
21 Sanden M, Ben-David M, Ashkenazi K, et al. Further validation of a MicroRNA-based assay for differential diagnosis of mesothelioma. Histopathology (Oxford). Oct. Suppl 1 Sp Iss. SI. 2012;61:165.
22 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
23 Food and Drug Administration. FDA/CDRH Public Meeting: Oversight of Laboratory Developed Tests (LDTs). 2010. http://www.fda.gov/MedicalDevices/NewsEvents/WorkshopsConferences/ucm212830.htm. Accessed 11/30/2012.
24 Erlander MG, Ma X-J, Kesty NC, et al. Performance and clinical evaluation of the 92-gene real-time PCR assay for tumor classification. J Mol Diagn. 2011;13(5):493-503. [pmid: 21708287].
25 Pentheroudakis G, Golfinopoulos V, Pavlidis N. Switching benchmarks in cancer of unknown primary: from autopsy to microarray. Eur J Cancer. Sep. 2007;43(14):2026-2036. [pmid: 17698346].
26 Hornberger JD I. Cost Effectiveness of Gene Expression Profiling for Tumor Site Origin. AACR IASLC joint conference on molecular origins of lung cancer: biology, therapy, and personalized medicine; 2012. January 10, 2012. San Diego, CA.
27 Frohling S, Dohner H. Chromosomal abnormalities in cancer. N Engl J Med. Aug. 14. 2008;359(7):722-734. [pmid: 18703475].
28 Chajut A, et al. Development and validation of a second generation microRNA-based assay for diagnosing tumor tissue origin. AACR. 2011.
29 Dumur CI, Fuller CE, Blevins TL, et al. Clinical verification of the performance of the pathwork tissue of origin test: utility and limitations. Am J Clin Pathol. Dec. 2011;136(6):924-933. [pmid: 22095379].
30 Dumur CI, Lyons-Weiler M, Sciulli C, et al. Interlaboratory performance of a microarray-based gene expression test to determine tissue of origin in poorly differentiated and undifferentiated cancers. J Mol Diagn. Jan. 2008;10(1):67-77. [pmid: 18083688].
31 Lal A, Panos R, Marjanovic M, et al. A gene expression profile test for the differential diagnosis of ovarian versus endometrial cancers. Oncotarget. Feb. 2012;3(2):212-223. [pmid: 22371431].
32 Meiri E, Mueller WC, Rosenwald S, et al. A second-generation microRNA-based assay for diagnosing tumor tissue origin. Oncologist. 2012;17(6):801-812. [pmid: 22618571].
33 Pillai R, Deeter R, Rigl CT, et al. Validation and reproducibility of a microarray-based gene expression test for tumor identification in formalin-fixed, paraffin-embedded specimens. J Mol Diagn. Jan. 2011;13(1):48-56. [pmid: 21227394].
34 Rosenfeld N, Aharonov R, Meiri E, et al. MicroRNAs accurately identify cancer tissue origin. Nat Biotechnol. Apr. 2008;26(4):462-469. [pmid: 18362881].
35 Rosenwald S, Gilad S, Benjamin S, et al. Validation of a microRNA-based qRT-PCR test for accurate identification of tumor tissue origin. Mod Pathol. Jun. 2010;23(6):814-823. [pmid: 20348879].
36 Varadhachary GR, Spector Y, Abbruzzese JL, et al. Prospective gene signature study using microRNA to identify the tissue of origin in patients with carcinoma of unknown primary. Clin Cancer Res. Jun. 15. 2011;17(12):4063-4070. [pmid: 21531815].
37 Ma XJ, Patel R, Wang X, et al. Molecular classification of human cancers using a 92-gene real-time quantitative polymerase chain reaction assay. Arch Pathol Lab Med. Apr. 2006;130(4):465-473. [pmid: 16594740].
38 Czechowski T, Stitt M, Altmann T, et al. Genome-wide identification and testing of superior reference genes for transcript normalization in Arabidopsis. Plant Physiol. Sep. 2005;139(1):5-17. [pmid: 16166256].
39 Beck AH, Rodriguez-Paris J, Zehnder J, et al. Evaluation of a gene expression microarray-based assay to determine tissue type of origin on a diverse set of 49 malignancies. Am J Surg Pathol. Jul. 2011;35(7):1030-1037. [pmid: 21602661].
40 Grenert JP, Smith A, Ruan W, et al. Gene expression profiling from formalin-fixed, paraffin-embedded tissue for tumor diagnosis. Clin Chim Acta. Jul. 15. 2011;412(15–16):1462-1464. [pmid: 21497155].
41 Kerr SE, Schnabel CA, Sullivan PS, et al. Use of a 92-gene molecular classifier to predict the site of origin for primary and metastatic tumors with neuroendocrine differentiation. Lab Invest. 2012;92:147A.
42 Kerr SE, Schnabel CA, Sullivan PS, et al. Multisite validation study to determine performance characteristics of a 92-gene molecular cancer classifier. Clin Cancer Res. Jul. 15. 2012;18(14):3952-3960. [pmid: 22648269].
43 Kulkarni A, Pillai R, Ezekiel AM, et al. Comparison of histopathology to gene expression profiling for the diagnosis of metastatic cancer. Diagn Pathol. Aug. 21. 2012;7(1):110. [pmid: 22909314].
44 Monzon FA, Lyons-Weiler M, Buturovic LJ, et al. Multicenter validation of a 1,550-gene expression profile for identification of tumor tissue of origin. J Clin Oncol. May. 20. 2009;27(15):2503-2508. [pmid: 19332734].
45 Mueller WC, Spector Y, Edmonston TB, et al. Accurate classification of metastatic brain tumors using a novel microRNA-based test. Oncologist. 2011;16(2):165-174. [pmid: 21273512].
46 Stancel GA, Coffey D, Alvarez K, et al. Identification of tissue of origin in body fluid specimens using a gene expression microarray assay. Cancer Cytopathol. Feb. 25. 2012;120(1):62-70. [pmid: 21717591].
47 Weiss L, Chu P. Blinded comparator study of immunohistochemistry (IHC) versus a 92-gene cancer classifier in the diagnosis of primary site in metastatic tumors. J Clin Oncol. 2012;30(15_suppl, May 20 Supplement):e21019.
48 Wu AH, Drees JC, Wang H, et al. Gene expression profiles help identify the tissue of origin for metastatic brain cancers. Diagn Pathol. 2010;5:26. [pmid: 20420692].
49 Wu F, Huang D, Wang L, et al. 92-gene molecular profiling in identification of cancer origin: A retrospective study in Chinese population and performance within different subgroups. PLoS One. 2012;7(6).
50 Azueta A, Maiques O, Velasco A, et al. Gene expression microarray-based assay to determine tumor site of origin in a series of metastatic tumors to the ovary and peritoneal carcinomatosis of suspected gynecologic origin. Hum Pathol. 2012. Aug. 30. [pmid: 22939961].
51 Greco FA, Spigel DR, Yardley DA, et al. Molecular profiling in unknown primary cancer: accuracy of tissue of origin prediction. Oncologist. 2010;15(5):500-506. [pmid: 20427384].
52 Hainsworth J, Pillai R, Henner DW, et al. Molecular tumor profiling in the diagnosis of patients with carcinoma of unknown primary site: retrospective evaluation of gene microarray assay. J Molec Bio and Diagn. 2011. http://www.pathworkdx.com/clinical_information/publications/. Accessed January 15, 2013.
53 Laouri M, Halks-Miller M, Henner WD, et al. Potential clinical utility of gene-expression profiling in identifying tumors of uncertain origin. Pers Med. 2011;8(6):615-622.
54 Monzon FA, Medeiros F, Lyons-Weiler M, et al. Identification of tissue of origin in carcinoma of unknown primary with a microarray-based gene expression test. Diagn Pathol. 2010;5:3. [pmid: 20205775].
55 Nystrom SJ, Hornberger JC, Varadhachary GR, et al. Clinical utility of gene-expression profiling for tumor-site origin in patients with metastatic or poorly differentiated cancer: impact on diagnosis, treatment, and survival. Oncotarget. Jun. 2012;3(6):620-628. [pmid: 22689213].
56 Pollen M, Wellman G, Lowery-Nordberg M. Utility of gene-expression profiling for reporting difficult-to-diagnose cancers. J Mol Diagn. 2011;13(6):764.
57 Schroeder BE, Laouri M, Chen E, et al. Pathological diagnoses in cases of indeterminate or unknown primary submitted for molecular tumor profiling. Lab Invest. 2012;92:105A-106A.
58 Thompson DS, Hainsworth JD. Molecular tumor profiling (MTP) in cancer of unknown primary site (CUP): A complement to standard pathologic diagnosis. J Clin Oncol. May. 20. 2011;29(15_suppl: May 20 Supplement):10560. 2011.
59 Laouri M, Nystrom JS, Halks-Miller M, et al. Impact of a gene expression-based tissue of origin test on diagnosis and recommendations for first-line chemotherapy. ASCO. 2010 June 4–8. Chicago, IL.
60 Pavlidis N, Pentheroudakis G. Accuracy of microRNA-based classification of metastases of unknown primary. J Clin Oncol. 2012;30. suppl abstr 10575.
61 McGee RS, Kesty NC, Erlander MG, et al. Molecular tumor classification using a 92-gene assay in the differential diagnosis of squamous cell lung cancer. Community Oncology. 2011;8(3):123-131.
62 Greco FA. Cancer of unknown primary site: evolving understanding and management of patients. Clin Adv Hematol Oncol. Aug. 2012;10(8):518-524. [pmid: 23073050].
63 Hainsworth JD, Schnabel CA, Erlander MG, et al. A retrospective study of treatment outcomes in patients with carcinoma of unknown primary site and a colorectal cancer molecular profile. Clin Colorectal Cancer. Jun. 2012;11(2):112-118. [pmid: 22000811].
64 Hainsworth JD, Spigel DR, Rubin M, et al. Treatment of carcinoma of unknown primary site (CUP) directed by molecular profiling diagnosis: a prospective, phase II trial. American Society of Clinical Oncology Annual Meeting. 2010. June. Abstract #10540.
65 Hainsworth JD, Rubin MS, Spigel DR, et al. Molecular gene expression profiling to predict the tissue of origin and direct site-specific therapy in patients with carcinoma of unknown primary site: a prospective trial of the Sarah Cannon Research Institute. J Clin Oncol. Jan. 10. 2013;31(2):217-223. [pmid: 23032625].
66 Hainsworth J, Henner D, Pillai R, et al. Molecular Tumor Profiling in the Diagnosis of Patients with Carcinoma of Unknow Primary (CUP): Retrospective Evaluation of the Tissue of Origin Test (Pathwork Diagnostics). ASCO-NCI-EORTC. 2010 October 18–20. Hollywood, FL.
67 Dumur CI, Ladd A, Ferreira-Gonzalez A, et al. Assessing the impact of tumor devitalization time on gene expression-based tissue of origin testing. Association for Molecular Pathology. 2008 October 29 – November 2. Grapevine, TX.
68 Barr FG, Chatten J, D’Cruz CM, et al. Molecular assays for chromosomal translocations in the diagnosis of pediatric soft tissue sarcomas. JAMA. Feb. 15. 1995;273(7):553-557. [pmid: 7530783].
69 Bridge RS, Rajaram V, Dehner LP, et al. Molecular diagnosis of Ewing sarcoma/primitive neuroectodermal tumor in routinely processed tissue: a comparison of two FISH strategies and RT-PCR in malignant round cell tumors. Mod Pathol. Jan. 2006;19(1):1-8. [pmid: 16258512].
70 Delattre O, Zucman J, Melot T, et al. The Ewing family of tumors--a subgroup of small-round-cell tumors defined by specific chimeric transcripts. N Engl J Med. Aug. 4. 1994;331(5):294-299. [pmid: 8022439].
71 Dumur CI, Blevins TL, Schaum JC, et al. Clinical verification of the Pathwork Tissue of Origin Test on poorly differentiated metastases. Association for Molecular Pathology. 2008 October 29 – November 2. Grapevine, TX.
72 Erlander MG, Ma X-J, Kesty NC, et al. Performance and Clinical Evaluation of the 92-Gene Real-Time PCR Assay for Tumor Classification. The Journal of Molecular Diagnostics. 2011;13(5):493-503. [pmid: 21708287].
73 Gamberi G, Cocchi S, Benini S, et al. Molecular diagnosis in ewing family tumors the rizzoli experience-222 consecutive cases in four years. J Mol Diagn. 2011;13(3):313-324. [pmid: 21458383].
74 Hainsworth J, Pillai R, Henner DW, et al. Molecular tumor profiling in the diagnosis of patients with carcinoma of unknown primary site: retrospective evaluation of gene microarray assay. J Molec Bio and Diagn. 2011. June. 27.
75 Lae ME, Roche PC, Jin L, et al. Desmoplastic small round cell tumor: a clinicopathologic, immunohistochemical, and molecular study of 32 tumors. Am J Surg Pathol. Jul. 2002;26(7):823-835. [pmid: 12131150].
76 Lewis TB, Coffin CM, Bernard PS. Differentiating Ewing’s sarcoma from other round blue cell tumors using a RT-PCR translocation panel on formalin-fixed paraffin-embedded tissues. Mod Pathol. Mar. 2007;20(3):397-404. [pmid: 17334332].
77 Mhawech-Fauceglia P, Herrmann F, Penetrante R, et al. Diagnostic utility of FLI-1 monoclonal antibody and dual-colour, break-apart probe fluorescence in situ (FISH) analysis in Ewing’s sarcoma/primitive neuroectodermal tumour (EWS/PNET). A comparative study with CD99 and FLI-1 polyclonal antibodies. Histopathology. 2006;49(6):569-575. [pmid: 17163841].
78 Patel RM, Downs-Kelly E, Weiss SW, et al. Dual-color, break-apart fluorescence in situ hybridization for EWS gene rearrangement distinguishes clear cell sarcoma of soft tissue from malignant melanoma. Mod Pathol. Dec. 2005;18(12):1585-1590. [pmid: 16258500].
79 Pillai R, Deeter R, Rigl CT, et al. Validation of a microarray-based gene expression test for tumors with uncertain origins using formalin-fixed paraffin-embedded (FFPE) specimens. J Clin Oncol. 2009;27. suppl abstr e20015.
80 Stancel GA, Coffey D, Alvarez K, et al. Identification of tissue of origin in body fluid specimens using a gene expression microarray assay. Cancer Cytopathol. 2011. Jun. 29. [pmid: 21717591].
81 Yamaguchi U, Hasegawa T, Morimoto Y, et al. A practical approach to the clinical diagnosis of Ewing’s sarcoma/primitive neuroectodermal tumour and other small round cell tumours sharing EWS rearrangement using new fluorescence in situ hybridisation probes for EWSR1 on formalin fixed, paraffin wax embedded tissue. J Clin Pathol. Oct. 2005;58(10):1051-1056. [pmid: 16189150].
82 Pavlidis NP G. Accuracy of microRNA-based classification of metastases of unknown primary. J Clin Oncol. suppl abstr 10575. 2012;30:2012.