# Result Synthesis and Strength of Evidence

We searched for articles on radiation treatments for prostate cancer published between January 2007 and December 2009 in MEDLINE® and Cochrane Central database and found 1,283 relevant citations. Abstract screening of these citations identified 165 potentially relevant articles. Full-text screening of these 165 articles identified 53 that met our eligibility criteria. We also added nine RCTs relevant to radiation treatments identified in the Minnesota report to our analysis. A total of 62 articles were included in our review.

The grand overview figure (Figure 2) detailed how many studies reported an outcome (either as a primary or secondary outcome) that is of interest. The total number of studies is greater than the number of unique studies as each study may have provided data for more than one outcome. Table 3 summarized the strength of evidence for the outcomes reported in each of the comparisons. Table 4 summarized only those comparisons with moderate level of evidence.

Figure 2 Number of comparative primary studies on radiation treatments for clinically localized prostate cancera

^a^Because no studies that compared between SBRT and EBRT, SBRT and HDR, SBRT and LDR, or EBRT vs. HDRBT were identified, these comparisons are not listed in this figure.

Table 3 Strength of evidence for radiation treatments of clinically localized prostate cancer

| High | Moderate | Insufficient
KQ1. Radiation therapy versus no treatment or no initial treatment
Freedom from Biochemical failure | | | X^a^
Disease Specific Survival | | | X^b^
GU/GI Toxicity | | | X^c^
KQ 2. Different forms or doses of radiation
SBRT versus EBRT | | | X^a^
SBRT versus HDRBT | | | X^a^
SBRT versus LDRBT | | | X^a^
EBRT versus HDRBT | | | X^a^
EBRT versus LDRBT
Freedom from Biochemical failure | | | X^b^
Disease Specific Survival | | | X^c^
GU/GI Toxicity | | | X^b^
LDRBT versus HDRBT
Freedom from Biochemical failure | | | X^c^
Disease Specific Survival | | | X^c^
GU/GI Toxicity | | | X^c^
Combined RT modality comparisons
Freedom from Biochemical failure | | | X^c^
GU/GI Toxicity | | | X^d^
Intra SBRT comparisons
Freedom from Biochemical failure | | | X^c^
GU/GI Toxicity | | | X^c^
Intra EBRT comparisons
Freedom from Biochemical failure | | X^e^
GU/GI Toxicity | | X^e^
Intra BT comparisons
Freedom from Biochemical failure | | | X^f^
GU/GI Toxicity | | | X^b^
KQ 3. Patient characteristics related to radiation treatment outcomes
Baseline risk (Stage, PSA, Gleason score) | | | X^b^
Gleason score/PSA levels | | | X^c^

a No study available

b Results inconsistent across studies

c Only one study

d Predominantly C quality studies

e ≥2 B quality RCTs that reported similar results (significant difference or no difference)

f Only one RCT and one retrospective study

Table 4 Comparisons with Moderate level of evidence

| Biochemical failure | Genitourinary toxicity | Gastrointestinal toxicity
EBRT dose comparisons | X^a^ | X^b^ | X^b^
EBRT fraction comparisons | X^c^ | X^c^ | X^c^

a Higher dose EBRT is associated with increased rates of freedom from biochemical failure at 5 to 10 years compared to lower dose EBRT

b Little or no difference between higher and lower dose EBRT

c Little or no difference between hypofractionation and standard fractionation arms

## Key question 1 radiation therapy versus no treatment or no initial treatment

(Figure 3)

The strength of evidence for comparing radiation therapy with either no treatment or no initial treatment was rated “insufficient” as all five eligible studies were retrospective analyses.14–18 These B-rated studies mostly provided data on different health outcomes. This makes it difficult to draw adequate conclusions regarding the same health outcome from the aggregate of the few qualified studies. The Minnesota review did not identify any RCTs that compared external beam radiation therapy with watchful waiting; neither did this update review.

Data from three retrospective cohorts showed mostly non-significant improvement in disease-specific survival in those patients who received radiation therapy compared with those who had either no treatment or no initial treatment.15–17

Only one study reported genitourinary toxicity outcome18 and found no difference between BT or EBRT and no treatment or no initial treatment, but higher rate of receiving urethral stricture treatment in patients treated with combined EBRT and BT, compared with those with no treatment or no initial treatment. One study reported incidence of second primary cancer,14 and found significantly higher rates of second primary cancer in patients treated with EBRT compared with those with no treatment or no initial treatment, but no difference between patients treated with BT and those with no treatment or no initial treatment.

Figure 3 Patient survival: radiation therapy vs. no treatment or no initial treatment

## Key question 2 different forms of radiation therapies

### SBRT vs. other radiation modalities; EBRT vs. HDRBT

There were no comparisons found between SBRT and any other radiation modality. There were also no comparisons between EBRT and HDRBT.

### LDRBT versus EBRT

(Tables 5, 6; Figure 4)

The strength of evidence for the comparative efficacy between LDRBT and EBRT on disease specific patient survival was rated “insufficient” as there was only one eligible study in this comparison. This B-rated retrospective comparison did not find a difference in disease specific patient survival comparing LDRBT with EBRT.17

The strength of evidence for the comparison between LDRBT and EBRT on biochemical control was rated “insufficient” because the results were inconsistent across the four B-rated retrospective studies.19–22 While two studies found better biochemical control in the LDRBT group compared with the EBRT group,21, 22 two studies did not find differences between groups.19, 20 (N.B. only three B studies were depicted in Figure 4, one B study was not depicted because it did not provide crude rates20).

Figure 4 Freedom from biochemical failure (5 years of follow-up): LDRBT vs. EBRT†

*Gondi (2007) comparing BT (with or without ADT) with EBRT (without ADT).

† Eade (2008) was not depicted here because only the actuarial rates and not the crude rates were reported.

Evidence for the comparative efficacy between LDRBT and EBRT for genitourinary and gastrointestinal toxicities was rated “insufficient” because the two prospective23, 24 and two retrospective20, 22 B-rated studies did not report consistent results. Two studies showed that LDRBT was associated with significantly more late genitourinary toxicity than EBRT, but no difference in acute toxicity20, 22 one study showed that LDRBT was associated with more genitourinary toxicity compared with EBRT but the result was non-significant23 and one study did not find significant difference in genitourinary toxicity between LDRBT and EBRT.24 For gastrointestinal toxicity, one study showed that LDRBT was associated with less gastrointestinal toxicity compared with EBRT;24 the other three studies did not find significant difference between LDRBT and EBRT.20, 22, 23

Regarding sexual dysfunction, one B-rated prospective cohort study showed significantly better outcomes with LDRBT compared with EBRT,24 another B-rated prospective cohort study also reported better outcomes with LDRBT compared with EBRT, but the P value of this result was not reported.23

Only one study reported cancer incidence.25 This B-rated retrospective cohort study showed a significantly lower incidence of bladder and rectal cancer with LDRBT compared with EBRT.

Table 5 Genitourinary toxicity: LDRBT vs. EBRT

Outcome | Interventions or comparisons (total sample size) | Study Findings | | Quality
Prospective cohort studies
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Sanda (2008) | Worse | B
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Ferrer (2008) | No diff | B
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Litwin (2007) or Gore (2009) | Worse^a^ | C
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Chen (2009): | | C
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with normal function at baseline | No diff
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with intermediate function at baseline | Better / Worse^b^
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with poor function at baseline | Worse
Retrospective cohort studies
Acute GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Eade (2008) | No diff | B
Acute GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Wong (2009) | No diff | B
Late GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Eade (2008) | Worse | B
Late GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Wong (2009) | Worse | B
Urethral strictures | LDRBT (N=158) vs. EBRT (N=216) | Eade (2008) | Worse | B
Incidence of bladder cancer (>10 years of follow-up) | LDRBT (N=22889) vs. EBRT (N=93059) | Nieder (2008) | Better | B

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing LDRBT with EBRT

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing LDRBT with EBRT

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing LDRBT with EBRT

Bold words signify statistical significance P<0.05

a Based on the Hazard Ratio of returning to baseline UCLA urinary score comparing the two groups

b Better for urinary incontinence score, and worse for urinary obstruction or irritation score

Table 6 Gastrointestinal toxicity: LDRBT vs. EBRT

Outcome | Interventions or comparisons (total sample size) | Study Findings | | Quality
Prospective cohort studies
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Sanda (2008) | No diff | B
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Ferrer (2008) | Better^a^ | B
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Litwin (2007) or Gore (2009) | No diff^b^ | C
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Chen (2009) | Better | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | LDRBT (N=275) vs. EBRT (N=767) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | LDRBT (N=275) vs. EBRT (N=767) | Lesperance (2008) | No diff | C
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Eade (2008) | No diff | B
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Lesperance (2008) | No diff | C
Incidence of rectal cancer (>10 years of follow-up) | LDRBT (N=22889) vs. EBRT (N=93059) | Nieder (2008) | Better | B

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing LDRBT with EBRT

No difference: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing LDRBT with EBRT

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing LDRBT with EBRT

Bold words signify statistical significance P<0.05

a Adjusted for pretreatment score, age at diagnosis, risk group and hormonal treatment using generalized equation models

b Based on the Hazard Ratio of returning to baseline UCLA bowel score comparing the two groups

### LDRBT vs. HDRBT

The strength of evidence for comparing LDRBT with HDRBT on biochemical outcome was rated “insufficient” as there was only one eligible study in this comparison. This C-rated retrospective cohort study compared HDR using Ir-192 (38 Gy or 42 Gy) with LDRBT using Pd-103 (120 Gy).26 The study did not find a difference in the 5-year freedom from biochemical failure and sexual dysfunction in the two groups. P values for the difference in genitourinary and gastrointestinal toxicities were not reported.

### Combination Therapies

(Tables 7, 8)

Evidence on the comparative efficacy of different combinations of radiation was rated “insufficient” as there were only a few studies in each of the comparisons.

There was no difference in biochemical failure between arms in one B-rated RCT comparing LDRBT plus EBRT in different doses.27

There was no difference in biochemical or clinical failure in one B-rated RCT comparing EBRT against EBRT plus HDRBT.28 One B-rated retrospective cohort study (Wong 2009) did not directly compare LDRBT plus EBRT against LDRBT but provided sufficient data for such a comparison; our own analysis showed no significant difference in biochemical control in these two arms.22

Our own analysis of the Wong 2009 study found an increase in late genitourinary toxicity in LDRBT plus EBRT compared with EBRT.22 One B-rated prospective cohort study reported non-significantly higher urinary dysfunction in patients who had EBRT plus LDRBT compared with EBRT plus HDRBT.29 A B-rated study found a significantly higher rate of urethral strictures in BT plus EBRT compared with EBRT.18

Table 7 Genitourinary toxicity: combinations of radiotherapies vs. EBRT or LDRBT

Outcome | Interventions or comparisons (total sample size) | Findings | | Quality
Prospective cohort studies
Disease-specific QoL: urinary scores | HDRBT+EBRT (N=49) vs. LDRBT+EBRT (N=61) | Lev (2009) | Better | B
Acute GU ≥ Grade 3 | HDRBT+EBRT (N=40) vs. EBRT (N=57) | Soumarova (2007) | No diff | C
Retrospective cohort studies
Disease-specific QoL: urinary scores | LDRBT+EBRT (N=15) vs. LDRBT (N=15) | Song (2008) | Worse | C
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Late GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | Worse | B
Late GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Late GU ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Urethral strictures | BT+EBRT (N=231) vs. EBRT (N=645) | Elliott (2007) | Worse | B

QoL, quality of life; diff, difference

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing first treatment listed with second treatment listed

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

Bold words signify statistical significance P<0.05

* The same LDRBT+EBRT group was compared to EBRT (IMRT) or LDRBT group

Table 8 Gastrointestinal toxicity: combinations of radiotherapies vs. EBRT or LDRBT

Outcome | Interventions or comparisons (total sample size) | Findings | | Quality
Prospective cohort studies
Disease-specific QoL: bowel scores | HDRBT+EBRT (N=49) vs. LDRBT+EBRT (N=61) | Lev (2009) | No diff | B
Acute GI ≥ Grade 3 | HDRBT+EBRT (N=40) vs. EBRT (N=57) | Soumarova (2007) | Better | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Late GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Late GI ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C

QoL, quality of life; diff, difference

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing first treatment listed with second treatment listed

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

Bold words signify statistical significance P<0.05

* The same LDRBT+EBRT group was compared to EBRT (IMRT) or LDRBT group

Our analysis of the data provided by a B-rated retrospective cohort study showed a higher rate of second primary cancers and late second primary cancers (≥ 5 years) in patients who had EBRT compared with those who had EBRT plus BT.14

One B-rated retrospective cohort study did not find significant difference in health-related quality of life between the EBRT group and EBRT plus HDRBT group.30

### Intra-SBRT comparisons

The strength of evidence for comparative efficacy of stereotactic body radiation therapy was rated “insufficient” as only one study31 qualified for inclusion in this review (see Appendix H for excluded studies specifically related to CyberKnife®). This C-rated retrospective cohort study with 304 patients and short follow-up found little difference in bladder and rectal toxicities between those who received 35 Gy in 5 fractions and those who received 36.25 Gy also in 5 fractions.

### Intra-EBRT Comparisons

Intra-EBRT studies compared different radiation dosages, fractions or modalities. We grouped these studies based on these comparisons.

#### EBRT Dose Comparisons

(Tables 9, 10; Figure 5)

The strength of evidence for EBRT dose comparison studies for freedom from biochemical failure was rated “moderate”. Data from three B-rated RCTs in five publications32–36 and five B-rated retrospective cohort studies37–40 suggest that the higher dose EBRT is associated with increased rates of freedom from biochemical failure at 5 to 10 years compared to lower dose EBRT.

Figure 5 Freedom from biochemical failure: EBRT dose comparisons (>5 years of follow-up)

$Kuban (2008) also provided 5-year follow-up data; *Eade (2007) also provided 5-year follow-up data; **Zietman 2010 provided follow-up data for patients originally reported in Zietman 2005

The strength of evidence for EBRT dose comparison studies for acute and late genitourinary or gastrointestinal grade 3 or greater toxicities was rated “moderate”. Data from five B-rated studies (one RCT,35 one prospective cohort,41 three retrospective cohort22, 38, 42) suggest that there is little or no difference in acute and late genitourinary or gastrointestinal toxicities between higher and lower dose EBRT.

Table 9 Genitourinary toxicity: EBRT dose comparisons

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GU ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Prospective cohort studies
Late GU ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N=400) | Michalski (2010) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N=400) | Lin (2007) | No diff | C
Retrospective cohort studies
Acute GU ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N=643) | Wong (2009) | No diff | B
Acute GU ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N=643) | Jani (2007) | No diff | C
| Higher (N=741^B^) vs. lower dose (N=830^B^) | Zelefsky (2008)^A^ | Higher is worse | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Goldner (2009) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Wong (2009) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Hanseen (2008) | No diff | C
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Jani (2007) | No diff | C
Late GU ≥ Grade 3 | High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | High is worse | B

Better: statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

No difference: no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Worse: statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Bold words signify statistical significance P<0.05

A ≥ Grade 2 GU toxicity

B estimated; as high (81 Gy) was only worse for those with IMRT, unclear how many without IMRT received high dose

Table 10 Gastrointestinal toxicity: EBRT dose comparisons

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GI ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Prospective cohort studies
Late GI ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Michalski (2010) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Lin (2007) | No diff | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N=643) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N=643) | Jani (2007) | No diff | C
| High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | No diff^A^
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Goldner (2009) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Hanseen (2008) | No diff | C
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N=799) | Jani (2007) | No diff | C
Late GI ≥ Grade 3 | High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | medium is worst | B

Better: statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

No difference: no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Worse: statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Bold words signify statistical significance P<0.05

A ≥ Grade 2 GI toxicity

#### Standard vs. Hypofractionation EBRT Comparisons

(Tables 11, 12)

The strength of evidence for EBRT fractionation comparison studies for freedom from biochemical failure was rated “moderate”. Data from three B-rated studies (two RCTs,43, 44 and one retrospective cohort45) suggest that there is no difference between hypofractionation and standard fractionation arms as performed for freedom from biochemical failure.

The strength of evidence for EBRT fractionation comparison studies for acute and late genitourinary/gastrointestinal grade ≥3 toxicities was rated “moderate”. Data from three B-rated studies (two RCTs,43, 46 one retrospective cohort45) suggest that there is little or no difference between hypofractionation and standard fractionation arms for acute and late gastrointestinal toxicities. One B-rated RCT showed that the acute genitourinary toxicity was significantly slightly higher in the hypofractionation arm compared with the standard fractionation arm but there was no difference in the late genitourinary toxicity.43 No differences were found in the acute or late genitourinary toxicity in the other studies.

Table 11 Genitourinary toxicity: EBRT fraction size comparisons

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GU ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | Long arm is better | B
Acute GU ≥ Grade 3 | Conventional fractionation (N=50) vs. hypofractionation IMRT (N=50) | Pollack (2006) | No diff | B
Late GU ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Retrospective cohort studies
Acute GU ≥ Grade 3 | Standard fractionation (N=74) vs. hypofractionation-3Gy/fraction (N=22) vs. hypofractionation-3.15Gy/fraction EBRT (N=34) | Leborgne (2008) | No diff | C
Late GU ≥ Grade 3 | Standard fractionation (N=130) vs. hypofractionation EBRT (N=89) | Leborgne (2009) | No diff | B

Better: statistically significant risk difference in increasing acute/late GI toxicity, comparing EBRT fraction sizes

No difference: no statistically significant risk difference in acute/late GI toxicity, comparing EBRT fraction sizes

Worse: statistically significant risk difference in decreasing acute/late GI toxicity, comparing EBRT fraction sizes

Bold words signify statistical significance P<0.05

Table 12 Gastrointestinal toxicity: EBRT fraction size comparisons

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GI ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Acute GI ≥ Grade 3 | Conventional fractionation (N=50) vs. hypofractionation IMRT (N=50) | Pollack (2006) | No diff | B
Late GI ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Retrospective cohort studies
Acute GI ≥ Grade 3 | Standard fractionation (N=74) vs. hypofractionation-3Gy/fraction (N=22) vs. hypofractionation-3.15Gy/fraction EBRT (N=34) | Leborgne (2008) | No diff | C
Late GI ≥ Grade 3 | Standard fractionation (N=130) vs. hypofractionation EBRT (N=89) | Leborgne (2009) | No diff | B

Better: statistically significant risk difference in increasing acute/late GI toxicity, comparing EBRT fraction sizes

No difference: no statistically significant risk difference in acute/late GI toxicity, comparing EBRT fraction sizes

Worse: statistically significant risk difference in decreasing acute/late GI toxicity, comparing EBRT fraction sizes

Bold words signify statistical significance P<0.05

#### Different variations of EBRT Comparisons

The strength of evidence for the following variations of EBRT administration was all rated insufficient as there was only one study for each variety of comparison.

One B-rated RCT compared EBRT with or without using endorectal balloon for prostate immobilization. 47 There were no differences in the acute and chronic genitourinary or gastrointestinal toxicity ≥ grade 3 in the two groups (no events in either group). In terms of chronic gastrointestinal toxicity ≥ grade 3 comparing EBRT with endorectal balloon versus without endorectal balloon, it was 0% versus 4% (no P value reported).

One C-rated prospective cohort study compared patients who received conformal radiotherapy to the prostate only (CRT-PO) with patients who received whole pelvis and prostate boost radiotherapy (WP+PB). 48 The study reported patients who had WP+PB had increased radiation induced fatigue compared with patients who had CRT-PO.

One B-rated retrospective cohort study evaluated the effect of different 3D-CRT nodal target coverage on biochemical failure-free survival (bFFS).49 Some patients had mini pelvis (MP) field treatment (excluding common iliac nodes) and some had whole pelvis (WP) field treatment (including common iliac nodes). This study observed that the pretreatment PSA level, Gleason score, T stage, and the use of ADTs were predictors of treatment response. An increase in bFFS in the MP field arm compared to the WP field arm was observed on univariate analysis, but not on multivariate analysis.

One C-rated retrospective study compared the effects of 3D-CRT versus 2D-CRT on anorectal function. There was no difference in the chronic grade ≥3 rectal toxicity at 2 years.50

### Intra-LDRBT comparisons

The strength of evidence for LDRBT dose comparison or radionuclide comparison studies for freedom from biochemical failure was rated “insufficient” because there were few studies within each comparison.

One B-rated RCT with three interim analyses found little or no difference between I-125 (144 Gy) and Pd-103 (125 Gy) in terms of freedom from biochemical failure at 3 to 6 years or genitourinary or gastrointestinal toxicities.51–53

One B-rated retrospective cohort study showed that higher biological effective dose (BED) (>220 Gy) using either I-125 or Pd-103 improved the overall survival rate and 5-year rate of freedom from biochemical failure compared with lower dose (≤220 Gy) in those with higher risk of prostate cancer progression (Gleason score 8 to 10).54, 55

One C-rated RCT comparing use and non-use of rectal protection with injection of hyaluronic acid among patients of LDRBT (I-125, 145 Gy) showed no difference in rectal bleeding.56

## Key question 3 patient characteristics as a modifier of outcomes of radiation therapies

(Table 13)

The strength of evidence for evaluating baseline risk as a modifier of outcomes of radiation therapies was rated “insufficient”. Five B-rated studies reported that treatment outcomes differed across low, intermediate, and high risk patient groups, but there were limited studies available for the comparisons reviewed.15, 22, 32, 40, 54

The strength of evidence for evaluating Gleason score and baseline PSA concentration as modifiers was also rated “insufficient” because there were only two eligible studies (one for each characteristic, both B-rated) that conducted the analyses.32, 33, 55 There was no difference in treatment outcomes between patients with different Gleason score or baseline PSA concentration.

Table 13 Effects of patient characteristics on treatment outcomes of different radiation therapies

Author Year [UI] | Treatment comparison | Analysis by factor of interest | Quality
Baseline risk on biochemical failure
Albertsen 2007 [17296379] | EBRT vs. observation | Low risk – ▲ survival rate in EBRT (P value not reported) Intermediate risk – ▲ survival rate in EBRT (P value not reported) High risk - ▲ survival rate in EBRT (P value not reported) | B
Kuban 2008 [17765406] | 3D-CRT 78 Gy vs. 70 Gy | Low risk – ▲ FFF in 78 Gy (P = 0.042) Intermediate risk – no difference High risk – ▲ FFF in 78 Gy (P = 0.004) | B
Stone 2007 [17689026] | BT < 140 Gy, 140–200 Gy, > 200 Gy | Low risk - ▲ FFF in higher dose (P < 0.0001) Intermediate risk - ▲ FFF in higher dose (P < 0.0001) High risk - ▲ FFF in higher dose (P < 0.0001) | B
Wong 2009 [19670452] | conventional dose 3D-CRT, high-dose IMRT, BT alone, or EBRT + BT | Low risk – no difference Intermediate risk – FFF: conventional dose 3D-CRT < BT alone < high-dose IMRT < EBRT + BT (P = 0.0003) High risk – no difference | B
Zelefsky 2008 [18280056] (452) | 3D-CRT or IMRT 70.2, 75.6, 81, 86.4 Gy | Low risk– no difference Intermediate risk– ▲ PSA-relapse free survival in the 75.6 Gy or 81 Gy group compared with 70.2 Gy or 86.4 Gy groups (P < 0.0001); ▲ rate of distant metastases free survival in 81 Gy compared with 75.6 Gy (P = 0.04) High risk– ▲ PSA-relapse free survival with ▲ dose (P < 0.0001); ▲ rate of distant metastases free survival in 81 Gy compared with 70.2 Gy (P = 0.01) | B
Baseline PSA concentration
Kuban 2008 [17765406] Pollack 2002 [2128107] | 3D-CRT 78 Gy vs. 70 Gy | PSA >10 ng/ml – ▲ FFF in 78 Gy (P < 0.001); no difference in rate of distant metastases free survival PSA ≤ 10 ng/ml – no difference | B
Gleason Score
Stone 2009 [18597953] | BT < 200 Gy, 200–220 Gy, >220 Gy | score 7 – no difference score 8–10 - ▲ FFF with ▲ dose (P < 0.001) | B
Interaction between baseline risk category and baseline PSA concentration
Kuban 2008 [17765406] Pollack 2002 [2128107] | 3D-CRT 78 Gy vs. 70 Gy | The difference in treatment between patients with PSA >10 ng/ml and patients with PSA <10 ng/ml was present among intermediate- and high-risk patients, but not among low-risk patients. | B

FFF: freedom from failure rate