# Methods

The objective of this technology assessment is to assess, using a systematic review approach, the volume and type of evidence available on radiation treatment for localized prostate cancer. The purpose is to provide a basis for establishing how the research field is evolving and identify areas that may require further research. We relied on findings from the 2008 comparative effectiveness review of therapies for clinically localized prostate cancer conducted by the Minnesota EPC (Wilt et al. Comparative effectiveness of therapies for clinically localized prostate cancer. Comparative Effectiveness Review No. 13. (prepared by Minnesota Evidence-based Practice Center under contract no. 290-02-0009) Rockville, MD: Agency for Healthcare Research and Quality, February 2008, available at effectivehealthcare.ahrq.gov/reports/final.cfm) as a springboard for our review. As the Minnesota review conducted its literature search through mid-September 2007, we conducted our literature search from January 2007 to ensure that all relevant and eligible studies are included. The methods for this technology assessment largely follows the methods suggested in the Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 published by AHRQ (available at effectiveheealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf). Please note that explanations for abbreviations of frequently used technical terms have been repeated several times throughout the entire document to help clarify highly technical terminologies. See Abbreviations for a list of abbreviations used for the entire document.

## Literature Search Strategy

Our search strategy used the National Library of Medicine’s Medical Subject Headings (MeSH) keyword nomenclature developed for Medline® and adapted for use in other databases. The searches were limited to the English language. The texts of the major search strategies are given in Appendix A.

We searched the Medline and the Cochrane Library from January 2007 to December 2009 for studies involving adults with clinically localized prostate cancer who underwent radiation treatments. We combined search terms or MeSH terms for prostate neoplasm and terms relevant to radiation therapy (e.g., proton beam, particle beam, external beam, radiotherapy, intensity-modulated radiotherapy, brachytherapy). We limited the search to English language studies in adult humans. We included peer reviewed, primary studies of radiation treatment for clinically localized prostate cancer that had reported either clinical or biochemical outcomes. We excluded case reports and conference abstracts. We did not search systematically for unpublished data. Our local domain expert provided additional relevant and eligible citations.

The identified abstracts results were reviewed independently by six reviewers. All abstracts concerning technical aspects of radiation therapy were re-screened by a radiation oncologist.

## Study Eligibility Criteria

Our three key questions concern mainly with radiation treatment. We focused only on direct comparative studies for this technology assessment. Because institutions sometime overhaul their radiation treatment in its entirety from one form to another form (e.g., switching from 3D-CRT to IMRT) and therefore direct comparative study between the different forms of treatment within the same institution would not be possible, we have relaxed this criterion to allow such studies as long as the patients were consecutively enrolled. We assessed titles and/or abstracts of citations identified from our literature search for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Results published only as abstracts were not included in our reviews because adequate information is not available to assess the validity of the data and these reports have generally not been peer-reviewed.

### Study designs of interest

We included randomized controlled trials and non-randomized direct comparative studies (same institution, contemporaneous or consecutive enrollment is permissible) of men with clinically localized disease and reported clinical outcomes for T1 or T2 disease (no less than 80% T1 or T2 if the study reported a mixed population including T3 and T4).

We did not place sample size and follow-up length restrictions on these comparative studies.

We excluded single cohort studies, adjuvant, salvage, or post-prostatectomy radiation therapy studies, and studies evaluating androgen deprivation therapy in conjunction with radiation therapy.

### Population and condition of interest

We included studies of men with clinically localized prostate cancer (T1-T2, N0-X, M0-X) regardless of age, histologic grade, PSA level, or whether they received hormonal treatments (provided the hormonal treatment was not a standard part of the overall treatment plan in one or both of the treatment arms). If the study did not clearly report T staging, we included the study only if it explicitly stated that it enrolled exclusively patients with localized or low risk disease.

### Interventions of interest

The intervention of interest was radiation treatment. The radiation treatment had to be used as a first line treatment of prostate cancer. The treatments included external beam radiation therapy (conformal radiation, intensity-modulated radiotherapy, proton therapy) stereotactic body radiation, and brachytherapy (low dose rate permanent seed implantation and high dose rate temporary brachytherapy). We also included combination radiation therapies, such as external beam radiation therapy with brachytherapy boost. For studies that also examined watchful waiting, active surveillance, or observation, because the study investigators did not use consistent definitions for these terms (e.g., some defined watchful waiting as no definitive treatment ever and some defined it as definitive treatment if disease progresses), we accepted all the different definitions and considered all three to be equivalent and grouped all three into “no treatment or no initial treatment” group.

### Comparators of interest

The comparators of interest were no treatment or no initial treatment (including watchful waiting and active surveillance) and alternate forms of radiation therapy.

### Outcomes of interest

Outcomes of interest included overall survival, prostate cancer-specific survival, biochemical (PSA), metastatic and/or clinical progression free survival, health status, and quality of life. Adverse events included anticipated events such as bowel, bladder, and sexual dysfunction and unanticipated events.

## Data Extraction

Data from each study were extracted by one of the reviewers and confirmed by another. The extracted data included information on patient samples, radiation treatment characteristics (e.g., type of radiation (proton vs. photon), source of radiation (linear accelerator, Cobalt-60, internally planted radioactive seeds), dose, number of fractions, and manufacturer of device), treatment planning algorithm, outcomes (clinical and biochemical), adverse events, and study design. For most outcomes, 6 months, 12 months, and/or only data from the last reported time point were included. We also evaluated potential sources of bias in the included studies with respect to adequate power, randomization, allocation concealment, intention to treat, adequate length of follow-up, number of dropouts and lost to follow-up. To minimize the possibility of between-EPC (Tufts and Minnesota) differences in interpretation of study findings, we elected to extract the data ourselves from those RCTs identified by the Minnesota report that were of relevance to this review.

## Quality Assessment

We used predefined criteria to grade study quality as A, B, or C. This system defines a generic grading system that is applicable to varying study designs including RCTs, nonRCTs, and observational studies. For RCTs, we mainly considered the methods used for randomization, blinding, as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described and how well they were reported. For nonRCTs and observational studies, the following elements were considered in assessing quality: clear reporting of eligibility criteria, similarity of comparative groups in terms of baseline characteristics and prognostic factors, reporting on crossovers, differential loss to follow-up between the comparative groups or overall high loss to follow-up, adjustment for potential confounders, and validity and adequacy of the description of outcomes and results.

### A (low risk of bias)

Studies rated “A” have the least bias and results are considered valid. These studies adhere mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.

### B

Studies rated “B” are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category “A”. The study may be missing information, making it difficult to assess limitations and potential problems.

### C (high risk of bias)

Studies rated “C” have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; there are large amounts of missing information, or major discrepancies in reporting.

## Rating the Body of Evidence

We assigned an overall grade describing the strength of evidence for each key question that was based on the number and quality of individual studies, duration of follow-up and the consistency across studies. The grades corresponded to the following definitions:

High – High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect. There is a high level of assurance with validity of the results for the key question based on at least two high quality studies with long-term follow-up of a relevant population. There is no important scientific disagreement across studies in the results for the key question.

Moderate – Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimates of effect and may change the estimate. There is a moderate level of assurance with validity of the results for the key question based on fewer than two high quality studies or in high quality studies that lack long-term outcomes of relevant populations. There is little disagreement across studies in the results for the key question.

Insufficient – Evidence is either unavailable or if available, a low level of assurance with validity of results for the key question. There could be disagreement across studies in the results for the key question.

The grades provide a shorthand notation of the strength of evidence supporting the answers to the key questions. However, they may oversimplify the many complex issues involved in appraising a body of evidence. The individual studies involved in formulating the composite grade differed in their design, reporting, and quality. As a result, the strengths and weaknesses of the individual reports addressing each key question would also be considered, as described in detail in the text and tables.

## Data Synthesis

For key question 1 (radiation treatment vs. no treatment or no initial treatment) and key question 2 (comparing different forms of radiation treatment), eligible studies were compiled into sets of summary tables that succinctly present the study features including design, patient-level and intervention-level characteristics, results, and study quality. For summarizing adverse events, as most studies used the Radiation Therapy Oncology Group adverse event classification scheme (rtog.org/members/toxicity/ctcmanual.html; rtog.org/members/toxicity/tox.html) in reporting genitourinary and gastrointestinal toxicities after radiation treatments, we have elected to enumerate only grade 3 or greater events in our summary as they are clinically much more serious than grade 1 or grade 2 events. We also used the grade 3 or greater results as proxy for all the toxicity events in the given category. We did not define acute and late adverse events in this review. We accepted definitions that were used in the individual studies (acute events were variably defined as those that occurred less than 3 to less than 6 months after radiation treatments; late events were therefore variably defined as those that occurred more than 3 to more than 6 months after radiation treatments). Result synthesis is presented in the main body of the report. Detailed results of the individual studies are presented in Appendices C to I.

### Forest plot

When more than one study provided sufficient data for calculating the effect sizes, we used forest plot to illustrate the relative strength of treatment effects across a set of studies that addressed the same research question (i.e., the same outcome and radiation therapy comparisons). For clinical outcomes, we employed the risk or rate difference (RD) as the metric of choice to quantify the effect size. For each study in the figure, the forest plot shows the effect size (represented by a square) and confidence intervals (represented by horizontal lines). A confidence interval crossing the vertical line of zero effect size indicates a non-statistically significant result. We noted at the bottom of the forest plot the interpretation of the risk or rate difference (e.g., favors LDRBT or favors HDRBT) on left and right side of the plot.

Studies that reported continuous outcomes (i.e., sexual dysfunction score, urinary dysfunction score, bowel dysfunction score, and quality of life score) are not included in the forest plots. Detailed results for these outcomes are summarized in various tables located in the appendices.