# Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Tufts EPC (Contract No. 290 2007 10055 I).

Prostate cancer is the most common noncutaneous malignancy diagnosed in men in United States. The American Cancer Society estimates that in 2009, approximately 192,000 men were diagnosed with prostate cancer, accounting for 25% of all new cancer cases, and that approximately 27,000 men died of the disease.1 Median age at diagnosis is 67 years (seer.cancer.gov/csr/1975_2006/results_single/sect_01_table.11_2pgs.pdf). However, autopsy studies suggest that 30% of men already have undiagnosed prostate cancer by age 40 and as many as 70–80% may have clinically “silent” prostate cancer by age 85.^2^ It has been estimated that approximately 50% of men undergo a routine prostate specific antigen (PSA) screening. Widespread PSA testing has doubled the incidence of prostate cancer, and results in the lifetime risk of prostate cancer of approximately 16% (seer.cancer.gov/statfacts/html/prost.html).

In addition to increasing incidence, PSA screening is also changing the characteristics of diagnosed prostate cancer. Data from the CaPSURE registry containing 8,685 men with biopsy-proven prostate cancer showed that the incidence of clinically “silent” T1 tumors (tumors diagnosed incidentally during transurethral resection of prostate for benign prostatic hypertrophy or tumors diagnosed by PSA screening, without clinical evidence by digital rectal exam) increased from 17% in 1989 to 48% in 2001.^3^ In the Prostate, Lung, Colorectal, and Ovarian Screening Trial (PLCO), 95% of patients were diagnosed with clinically localized disease, while only 1.6% were diagnosed with locally advanced disease, and 2.4% were diagnosed with metastatic disease.4 Overall, the vast majority of patients diagnosed today have clinically localized prostate cancer (T1-T2N0), which is the subject of this report.

To appreciate the impact of treatment interventions, it is important to understand the natural history of untreated clinically localized prostate cancer. Our understanding of this process is limited because of the stage shift to earlier disease with PSA screening discussed above. Investigators from a European prostate cancer screening trial (ERSPC) have estimated that the mean lead time bias for screening-detected cancers versus clinically-detected cancers could be 11.2 years, with an estimated overdetection rate of 50%.5 This suggests that after PSA diagnosis of prostate cancer (Stage T1c), it can take more than 10 years before the disease becomes clinically apparent. The natural history of prostate cancer diagnosed clinically is better characterized based on data from pre-PSA era. A cohort study from Sweden tracked 223 patients with localized prostate cancer diagnosed between 1977 and 1984, with a median follow-up of 21 years.6 Most of the cancers had an indolent course during the first 15 years of follow-up, with progression-free survival of 45%, distant metastasis-free survival of 77%, and prostate cancer-specific survival of 79%. However, between 15 and 20 years of follow-up, there was a significant decrease in progression-free survival to 36%, distant metastasis-free survival to 51%, and prostate cancer-specific survival of 54%. The authors concluded that most prostate cancer patients diagnosed clinically at an early stage have an indolent course, but aggressive metastatic disease may develop in the long term. A similar cohort study from Connecticut tracked 767 patients with localized prostate cancer diagnosed between 1971 and 1984.^7^ Their 20-year prostate cancer-specific survival was 71% and overall survival was 7%. The 20-year cancer-specific survival for patients with a low grade (Gleason Score 2–6) was 81%, with intermediate grade (Gleason Score 7) was 55%, and with high grade (Gleason Score 8–10) was 34%. In contrast to the Swedish study, there was no worsening of cancer-specific survival after 15 years. Extrapolating from these studies, the natural history for an average 70 year old patient diagnosed today could result in the development of clinically evident disease in 10 years and a 50% chance of survival from prostate cancer in 30 years after diagnosis, though the rate would be dependent on initial grade of the tumor. To put these numbers into perspective, for that average 70 year old man the probability of survival for 10 years (when he would develop clinically evident disease) is 65% and the probability of survival for another 30 years (when he would have a 50% risk of dying from prostate cancer) is less than 1% (ssa.gov/OACT/STATS/table4c6.html).

Because of the differential survival rates based on tumor grade, there has been an increased focus on identifying and treating patients with aggressive subtypes whose overall survival is likely to be impacted by their cancer, while deferring treatment for patients with indolent subtypes and/or short life-expectancy, whose overall survival is not likely to be impacted by their cancer. Depending on patient’s risk profile, there are numerous treatment options available, which include active surveillance (deferred initial therapy; with continued surveillance and predetermined action levels that will trigger definitive therapy), watchful waiting (either the same as active surveillance or as no definitive therapy regardless of disease progression, until death), surgery, radiation therapy, cryotherapy, high intensity focused ultrasound, and androgen deprivation therapy. For the purpose of this report, watchful waiting is considered equivalent to active surveillance, and the No Treatment or No Initial Treatment comparator category in Key Question 1 (see below) includes active surveillance, watchful waiting, and observation. Currently, the National Comprehensive Care Network guidelines represent a standard of care in United States, and the NCCN prostate cancer guideline outlines which treatment options may be appropriate for which patients (nccn.org/professionals/physician_gls/PDF/prostate.pdf).

A Comparative Effectiveness Review of Therapies for Clinically Localized Prostate Cancer was undertaken on behalf of the Agency for Healthcare Research and Quality (AHRQ) by the Minnesota Evidence-based Practice Center (EPC) in 2007 (Wilt et al. Comparative effectiveness of therapies for clinically localized prostate cancer. Comparative Effectiveness Review No. 13, prepared by Minnesota Evidence-based Practice Center under contract no. 290-02-0009 Rockville, MD: Agency for Healthcare Research and Quality, February 2008. Available at effectivehealthcare.ahrq.gov/reports/final.cfm). The report concluded that “No one therapy can be considered the preferred treatment for localized prostate cancer due to limitations in the body of evidence as well as the likely tradeoffs an individual patient must make between estimated treatment effectiveness, necessity, and adverse effects. All treatment options result in adverse effects (primarily urinary, bowel, and sexual), although the severity and frequency may vary between treatments. Even if differences in therapeutic effectiveness exist, differences in adverse effects, convenience, and costs are likely to be important factors in individual patient decision making.” As more studies on radiation treatments have been published since the Minnesota report, the Centers for Medicare and Medicaid Services (CMS) is interested in an update. After consultation with AHRQ and CMS, this technology assessment has been commissioned specifically to examine the recent comparative studies on radiation treatments of prostate cancer.

Radiation therapy uses high-energy ionizing radiation to damage DNA of tumor cells, ultimately causing cell death and resulting in tumor eradication. As part of the radiation treatment, surrounding normal tissues are also irradiated, resulting in death of normal cells, and leading to development of side effects. There are three fundamental questions involved with the delivery of radiation to a tumor: 1) What should be the actual target of radiation? 2) How do we deliver radiation to it most effectively and safely? 3) What dose scheme will we use? Understanding these questions will help to understand the evolution of radiation technology and current efforts at further advances.

From a technology perspective, there are multiple methods of delivering radiation to the prostate, and these are summarized in Figure 1. Radiation can be delivered from outside the body using man-made accelerators, which is known as teletherapy or external beam radiation therapy (EBRT). Or it can be delivered by implanting naturally radioactive elements directly into the tumor, which is known as brachytherapy (BT). The process of planning a treatment and delivering radiation therapy is different, depending on whether EBRT or BT is used. For EBRT, the first step involves acquiring a planning CT scan of the patient to outline the tumor. The next step is to virtually plan the treatment using computer models to ensure that radiation is delivered safely and effectively. Finally, the patient comes for the treatment itself, which is typically delivered in multiple sessions called fractions. For BT, treatment planning can be done either prior to the surgical implant in a similar fashion as for EBRT or it can be done inside the operating room at the time of the implant of radioactive sources, usually using ultrasound guidance.

## Actual target of radiation

The extent of the irradiation area (field size) is an important issue, because the larger the area treated, the more normal tissues are incidentally irradiated, and the more frequent and severe the side effects (conversely, the smaller the field size, the more likely that the entire tumor will not be adequately treated). Field size is driven both by clinical decisions about the extent of disease, as well as by technical factors regarding prostate visualization and prostate motion. Many technological advances in radiation therapy focus on minimizing the treated volume to minimize toxicity. Prostate cancer typically arises in multiple foci within the prostate gland, and thus far no imaging methods have been able to reliably identify involved areas of the prostate. For now, the entire prostate gland typically serves as the target for radiation. For some prostate tumors, there can be subclinical microscopic extension outside of the prostate into the surrounding tissues, seminal vesicles, and regional lymph nodes. There is no definitive evidence available to guide radiation oncologists on when to treat just the prostate gland, when to irradiate some of the surrounding tissues, when to irradiate the seminal vesicles, and when to treat the lymph nodes. First efforts at targeting the prostate used plain x-rays for visualization. Unfortunately, the prostate gland cannot be reliably distinguished from the surrounding soft tissues on plain films. This method of treatment planning is called two-dimensional planning. Development of CT scans for treatment planning in the 1980’s resulted in better visualization of the prostate gland and the lymphatic drainage. The ability to outline the target in three dimensions led to 3D planning, which is the standard today. However, there is a wide variability among individual radiation oncologists in outlining the shape and location of the prostate gland or the lymphatic drainage.8, 9 MRI scans are able to better distinguish the soft tissue densities of the prostate and peri-prostatic tissue, and are becoming a more common tool for radiation oncologists to delineate the radiation target.

Another factor complicating the determination of tumor location is the fact that the planning CT scan is a momentary snapshot in time that shows only where the prostate gland happens to be during the scan. From day to day (inter-fraction motion), and even from minute to minute during treatment (intra-fraction motion), the prostate can move significantly.10 The location of the prostate is determined by a number of factors, including the volume of rectal filling and the amount of bladder filling. If we do not know where the prostate may be at any given moment, we need to treat the entire area where it could potentially be, and thus irradiate unnecessarily significant amount of normal tissues. There are three broad strategies to deal with the motion of the prostate: 1) improved immobilization of the prostate, 2) increased frequency of localizing (imaging) the prostate over time, 3) implanting radiation directly into the prostate, such that the sources move with the prostate.

There are a number of immobilization techniques or devices employed during external beam radiation therapy, such as abdominal compression, endorectal balloon, foot holders, knee supports, and pelvic immobilizers, which attempt to more reproducibly fix the position of the prostate. In terms of prostate localization for treatment, patients used to be positioned on the treatment table every day using external skin tattoos, and their position would be verified once per week using bony landmarks on x-ray. Advancements in localization have included using daily imaging prior to each treatment session with ultrasound, x-rays combined with implanted fiduciary markers, and on-board CT scans. This approach eliminates daily (inter-fraction) variability in prostate position resulting from bladder and rectal filling. However, there is still the issue of intra-fraction mobility during the treatment itself. Two approaches are currently used to address this problem: implanted fiducial markers into the prostate that are tracked continuously during the treatment using electromagnetic fields (Calypso System from Calypso Medical Technologies), or implanted fiducial markers that are tracked prior to each treatment beam every few seconds (CyberKnife® from Accuray Inc., Sunnyvale, CA).

Implanting radiation directly into the target is another method of improving dose delivery. There are two forms: 1) permanent implantation of many radioactive seeds into the prostate, which will deliver their radiation dose over the course of weeks to months, and is known as low dose rate brachytherapy (LDRBT), and 2) temporary implantation of catheters into the prostate, through which radioactive seeds are temporarily placed and deliver their radiation dose over the course of minutes, and is known as high dose rate brachytherapy (HDRBT). The downside of this approach is that it is an operative procedure and that radiation can only be delivered to the prostate, and not easily to seminal vesicles or lymph nodes.

## Delivering radiation effectively and safely

Planning the radiation treatment involves generating a virtual model of the patient and mathematically estimating the dose that the tumor and the surrounding normal tissues will receive during treatment. The dose to each individual patient is actually not known; the estimated dose is verified by irradiating a physical model or an x-ray film and measuring the delivered dose. There are several different models of radiation deposition available. Initially, plain x-rays were used for treatment planning, and the amount of dose given was only calculated for few points within the patient. Using this approach, the amount of radiation actually received by the various parts of the prostate and by the surrounding normal organs was essentially unknown. This process is known as conventional radiation or 2D-radiation. When CT scans became incorporated into the treatment planning process, the prostate gland as well as the surrounding organs could be individually identified. The treatment planning software allowed the calculation of dose at any point in the 3-D space, allowing for a much more precise estimate of dose to the target and to surrounding normal organs. In addition, radiation could be targeted more tightly around the prostate to decrease irradiation of surrounding normal tissues. This process is known as 3D-conformal radiation (3D-CRT). The next improvement came with the ability to change the intensity of the radiation beam itself, while the radiation was being delivered. This process is known as intensity modulated radiation therapy (IMRT), and allows much more precise control over where the radiation is deposited. As discussed in the prostate localization section, incorporation of daily pre-treatment imaging allowed further precision in targeting the radiation, and is known as image-guided radiation therapy (IGRT). IMRT and IGRT are typically used together, such that the position of the beam is adjusted prior to every treatment (IGRT), and the radiation intensity of the beam is modulated once the treatment begins (IMRT). Further incorporation of various body immobilization systems into IMRT with IGRT, together with increased daily dose, and limiting the number of treatments to one or few, is known as stereotactic body radiation therapy (SBRT)11. An alternative means of delivering radiation therapy using external beam to the prostate involves proton therapy, using exactly the same process as the standard photon EBRT, but using proton particles instead. Despite the technical advances in delivery of external beam radiation, it may not possible to deliver sufficiently high dose without incurring unacceptable normal tissue toxicity. In these instances, efforts are under way to combine EBRT with brachytherapy for dose escalation, either as EBRT + HDRBT or EBRT + LDRBT (Table 1).

## Dose schema used in radiation delivery

The unit of absorbed radiation dose is Gray (Gy), which corresponds to absorption of one joule of energy by one kilogram of matter. Historically, dose in prostate cancer was delivered in 1.8 – 2.0 Gy per treatment (fraction). Before development of 3D-CRT (see above), maximum tolerable dose was approximately 70 Gy delivered in 35 fractions over 7 weeks, above which unacceptable toxicity resulted. With technology developments described above, dose escalation over 80 Gy has been employed. Current NCCN guidelines recommend 75.6 to 80+ Gy doses, delivered over 7–8 weeks. There is some evidence that prostate cancer may be better treated with larger doses per fraction (> 2 Gy) than is currently standard.12 To account for the fact that a larger dose per fraction results in dramatically more DNA damage and subsequently cell kill, it is important to convert the physical dose to biologically-equivalent dose (BED).13 Using this concept, a regimen of 7 Gy per fraction for 5 treatments (absolute dose 35 Gy) could result in biologically equivalent tumor control to an IMRT regimen of 2 Gy per fraction for 42 fractions (absolute dose 84 Gy); absolute dose comparisons between different regimens may not be meaningful if the dose per fraction is not the same.

## Key questions for this report

Understanding the process of delivering radiation therapy described above is crucial to comprehend this technology assessment. This report addressed the following key questions:

1. What are the benefits and harms of radiation therapy for clinically localized prostate cancer compared to no treatment or no initial treatment (watchful waiting, active surveillance, or observation) in terms of clinical outcomes?
2. What are the benefits and harms of different forms of radiation therapy for clinically localized prostate cancer in terms of clinical outcomes? The comparisons of interest are between the following radiation modalities: stereotactic body radiation therapy (SBRT, including CyberKnife® therapy), classically fractionated external beam radiation therapy (EBRT, including 3D-conformal radiation therapy, intensity modulated radiation therapy, and particle therapy), high dose rate brachytherapy (HDRBT), and low dose rate brachytherapy (LDRBT, including permanent brachytherapy). These modalities will be specifically compared with each other, i.e., LDRBT VS. EBRT, HDRBT VS. LDRBT, SBRT vs. EBRT, SBRT vs. HDRBT, SBRT vs. LDRBT, EBRT vs. HDRBT, combination therapies, intra-SBRT comparisons, intra-EBRT comparisons, and intra-BT comparisons.
3. How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbidities, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression) affect the outcomes of these different forms of radiation therapy?

Figure 1 Overview of radiation therapy modalities

2D RT is two-dimensional radiation therapy; 3D CRT is three dimensional conformal radiation therapy; IMRT is intensity modulated radiation therapy; IGRT is image-guided radiation therapy; I-125, Pd-103, Cs-131, and Ir-192 are radionuclides used in brachytherapy

Table 2 Comparison of external beam radiation therapy (EBRT) modalities

| CT Treatment Planning | Beam Intensity Modulation | Frequent Imaging | Stereotactic Immobilization | 1–5 Treatment Fractions
2D RT
3D CRT | X
IMRT | X | X
IGRT | X | X | X
SBRT | X | X | X | X | X
Proton Therapy | X | +/− | X | X | +/−