# Future Research

Whether there is a benefit of radiation treatments compared to no treatment or no initial treatment for men with localized prostate cancer in the PSA era, and for which men, is not clear. To definitively evaluate the effects of radiation treatments compared to no treatment or no initial treatment, well-conducted RCTs with very long follow-up are needed. There are now two ongoing randomized trials enrolling over 2,000 patients each, comparing active surveillance to radical prostatectomy and radiation therapy. The Canadian-sponsored START trial is planning to enroll 2,130 men, with estimated primary completion date of April 2023 (NCT00499174 (http://clinicaltrials.gov/ct2/show/NCT00499174)). The British ProtecT trial is planning to enroll 2,050 men, with estimated primary completion date of December 2013 (NCT00632983). Results from these trials should help to answer the questions of which men can be safely observed and which men need therapy, and how radiation therapy and radical prostatectomy compare to each other as the primary treatment approach.

As our review has shown, the available evidence does not permit one to assess the optimal dose and fractionation schedule for external beam radiation therapy. There are at least 4 ongoing trials examining different hypofractionated schedules (NCT00331773 (http://clinicaltrials.gov/ct2/show/NCT00331773), NCT00392535 (http://clinicaltrials.gov/ct2/show/NCT00392535), NCT00667888 (http://clinicaltrials.gov/ct2/show/NCT00667888), NCT00304759 (http://clinicaltrials.gov/ct2/show/NCT00304759)). But no trials evaluating hypofractionation used or are using fewer than 15 fractions, including schedules using one to few fractions currently being delivered with high-dose rate brachytherapy and stereotactic body radiation therapy. Randomized trials to address the question of such approaches using one to few fractions (SBRT or HDRBT) should be conducted.

Randomized comparisons of brachytherapy and external beam radiation therapy will also be useful in clarifying the potential relative benefits and harms of the two forms of radiation therapy. The data gathered will help improve counseling of patients as some patients treated now with brachytherapy may also be good candidates for active surveillance.

Our current review did not identify any comparative studies evaluating the role of particle radiation therapy (e.g., proton) in the treatment of prostate cancer. Data from such studies will help decide how to best use these limited resources.

To definitively assess which form and dose of radiation delivered is optimal in minimizing toxicities and prolonging survival and at the same time taking into account patients’ own preferences is not a simple task. It would be ideal if one always has the resources to conduct a well-designed RCT to make this assessment. As this is not always possible, a prospectively designed cohort study taking into account important confounders along with a cost-effective method for appropriate long-term follow-up may be more pragmatic under certain circumstances. Retrospective analysis, with its attendant limitations (detailed in Discussion), will continue to be conducted. One is reminded that findings from retrospective analyses are sometimes useful in generating hypotheses for new experimental trials and may also provide valuable data on anticipated and unanticipated adverse events related to the various treatments.

Lastly, as has been mentioned earlier, no studies that we reviewed for this technology assessment reported safety data related to the delivery of radiation (e.g., errors in planning software, operator errors, machine malfunctions), it is vital that safety in radiation delivery be actively monitored and diligently recorded for every patient undergoing any form of radiation treatment.