# Discussion

Because prostate cancer tends to have a long clinical course typically measured in decades, many studies focused on short term adverse events or biochemical control rather than long term clinical efficacy outcomes like metastases and disease-specific mortality. It should be noted that in the studies reviewed, the event rates for grade 3 or greater urinary or bowel toxicity is so low that any statistically significant differences between treatment arms may not translate into substantive clinical differences. It should also be underscored that none of the studies provided adverse events data related to the administration of radiation treatments themselves (e.g., errors in treatment planning software and radiation equipment operation leading to adverse outcomes).

Many of the findings reported in this review were inconsistent for each of the outcomes of interest. The studies reviewed showed substantial heterogeneity. Even among patients with T1 or T2 prostate cancer, the underlying risk of prostate cancer progression varies widely, as this risk is also dependent on Gleason score, pretreatment PSA concentration, and other factors. An important weakness in many of these comparative analyses is that patients were given treatments tailored to their individual risk profile (e.g., patients with low risk prostate cancer tend to be given BT versus those with intermediate risk prostate cancer tend to be given EBRT); this makes it difficult, if not impossible, to assess the comparative efficacies between two forms of radiation treatments as the underlying risk of prostate cancer progression in the two groups of patients may be fundamentally different. Another problem is the fact that many of the techniques of radiation delivery reported in the observation cohorts had evolved over the study period of interest. As a result, one could never be certain that one form of radiation delivered to one patient at one time point is comparable to the “same” form of radiation delivered to another patient at another time point. Some of the other limitations in these analyses include the use of historical controls and lack of adjustment for potential confounders.

As had been noted in the Minnesota report, patients from minority groups were underrepresented in the studies reviewed. Although no study examined whether outcomes of different radiation treatments differ among racial groups, Rose et al. reported that the probability of receiving any aggressive therapy or BT did not differ between patients of non-Hispanic black and non-Hispanic white races.57 However, non-Hispanic white patients were more likely to receive radical prostatectomy and less likely to receive radiation therapy when compared with non-Hispanic blacks.

Many of the studies did not report a power calculation. Even though some of the studies included cohorts with relatively large numbers of subjects (thousands), it is plausible that, in fact, the included studies may have been underpowered to detect the true effect sizes. Also, the blinding of patients to the intervention as well as that of investigators who measured the outcomes of interest was rarely reported.

The focus of this review is clinically localized prostate cancer (stages T1 and T2). The majority of the patients in these studies had clinically localized disease (stage T1 and T2); however, approximately one-third of the studies reviewed included up to 20% of patients with stage T3 or higher disease. Excluding them would lead to a drastically reduced number of qualified studies and may inadvertently discard useful data. Similarly, approximately half of the studies had some patients who received androgen deprivation therapies (ADTs), either as a neoadjuvant, concurrent or adjuvant therapy. Many of the studies that included patients with stage T3 or higher disease or ADTs did not report results stratified by patients’ tumor stage or ADT use. Therefore, we are not always able to draw conclusions on the specific treatment effects of the different forms of radiation alone for clinically localized prostate cancer patients (stage T1 and T2), without contamination of results from patients with stage T3 or higher disease, or without contamination of results from patients also treated with ADTs. How these contaminations would affect the “true” treatment effect estimate of radiation alone in only T1-T2 disease is unpredictable.

Further complicating our analysis are the heterogeneous definitions used in the various outcomes of interest. For example, for urinary and bowel toxicity, even though the majority of the studies used the Radiation Therapy Oncology Group (RTOG) classification scheme, a minority of the studies reported the actual events (e.g., urinary urgency, rectal bleeding) without using the RTOG scheme. Some studies classified biochemical failure strictly using PSA concentration characteristics; some studies classified clinical failure (without PSA characterization) as a subgroup of biochemical failure. All these differences make cross-study comparison challenging.

Similar to the Minnesota review, we did not identify any completed RCTs that compared the benefits and harms between no treatment or no initial treatment and radiation therapy. Currently, two trials are being carried out to evaluate this question (see further details in Future Research). The number of trials is small. This is likely due to the long survival of those patients with localized disease which poses logistic and financial constraints in conducting trials with long duration of follow-up and the pragmatic difficulty of informing prospective enrollees about the clinical equipoise of watchful waiting and radiation therapy as opinions on these two different options abound on the web and among the different specialists taking care of patients with prostate cancer.

Of note, as an a priori decision for this technology assessment, we only looked at the direct evidence comparing radiation treatment with no treatment (or no initial treatment) or one form of radiation treatment versus another form of radiation treatment. We did not examine the indirect evidence from cohort studies or other forms of comparisons. We are aware that one randomized trial comparing radiation therapy with concurrent androgen deprivation therapy to androgen deprivation therapy alone in patients with predominately T3 stage prostate cancer reported a survival benefit for the concurrent radiation therapy arm.58 While this trial argues indirectly for a beneficial effect of radiation therapy in the treatment of such patients, direct comparative study should be undertaken in appropriately selected clinically localized prostate cancer patients to either confirm or refute this conjecture.