# Bibliography (alphabetical)

Reference | PMID
Abdel-Wahab M, Reis IM, Hamilton K. Second primary cancer after radiotherapy for prostate cancer--a seer analysis of brachytherapy versus external beam radiotherapy. International Journal of Radiation Oncology, Biology, Physics 72 (1):58 -68. 2008. | 18374503
Albertsen PC, Hanley JA, Fine J. 20-year outcomes following conservative management of clinically localized prostate cancer. JAMA 293 (17):2095 -101. 2005. | 15870412
Albertsen PC, Hanley JA, Penson DF, Barrows G, Fine J. 13-year outcomes following treatment for clinically localized prostate cancer in a population based cohort. Journal of Urology 177 (3):932 -6. 2007. | 17296379
Andriole GL, Crawford ED, Grubb RL, III et al. Mortality results from a randomized prostate-cancer screening trial.[Erratum appears in N Engl J Med. 2009 Apr 23;360(17):1797]. New England Journal of Medicine 360 (13):1310 -9. 2009. | 19297565
Chen RC, Clark JA, Talcott JA. Individualizing quality-of-life outcomes reporting: how localized prostate cancer treatments affect patients with different levels of baseline urinary, bowel, and sexual function.[see comment]. Journal of Clinical Oncology 27 (24):3916 -22. 2009. | 19620493
Cooperberg MR, Lubeck DP, Mehta SS, Carroll PR, CaPSURE. Time trends in clinical risk stratification for prostate cancer: implications for outcomes (data from CaPSURE).[Erratum appears in J Urol. 2004 Feb;171(2 Pt 1):811]. Journal of Urology 170 (6 Pt 2):S21 -5; discussion S26 -7. 2003. | 14610406
Danjoux C, Gardner S, Fitch M. Prospective evaluation of fatigue during a course of curative radiotherapy for localised prostate cancer. Supportive Care in Cancer 15 (10):1169 -76. 2007. | 17333296
Draisma G, Boer R, Otto SJ et al. Lead times and overdetection due to prostate-specific antigen screening: estimates from the European Randomized Study of Screening for Prostate Cancer. Journal of the National Cancer Institute 95 (12):868 -78. 2003. | 12813170
Eade TN, Hanlon AL, Horwitz EM, Buyyounouski MK, Hanks GE, Pollack A. What dose of external-beam radiation is high enough for prostate cancer?[see comment]. International Journal of Radiation Oncology, Biology, Physics 68 (3):682 -9. 2007. | 17398026
Eade TN, Horwitz EM, Ruth K et al. A comparison of acute and chronic toxicity for men with low-risk prostate cancer treated with intensity-modulated radiation therapy or (125) I permanent implant. International Journal of Radiation Oncology, Biology, Physics 71 (2):338 -45. 2008. | 18207665
Elliott SP, Meng MV, Elkin EP et al. Incidence of urethral stricture after primary treatment for prostate cancer: data From CaPSURE. Journal of Urology 178 (2):529 -34. 2007. | 17570425
Ferrer M. Health-related quality of life 2 years after treatment with radical prostatectomy, prostate brachytherapy, or external beam radiotherapy in patients with clinically localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics 72 (2):421-32. 2008. | 18325680
Goldner G, Bombosch V, Geinitz H et al. Moderate risk-adapted dose escalation with three-dimensional conformal radiotherapy of localized prostate cancer from 70 to 74 Gy. First report on 5-year morbidity and biochemical control from a prospective Austrian-German multicenter phase II trial. Strahlentherapie und Onkologie 185 (2):94 -100. 2009. | 19240995
Gondi V, Deutsch I, Mansukhani M et al. Intermediate-risk localized prostate cancer in the PSA era: radiotherapeutic alternatives. Urology 69 (3):541 -6. 2007. | 17382161
Gore JL, Kwan L, Lee SP, Reiter RE, Litwin MS. Survivorship beyond convalescence: 48-month quality-of-life outcomes after treatment for localized prostate cancer. [see comment]. Journal of the National Cancer Institute 101 (12):888 -92. 2009. | 19509365
Hall, EJ and Giaccia, AJ. Radiobiology for the Radiologist. 6^th^ ed. Lippincott Williams & Wilkins; 2005 | ISBN-10: 0781741513
Hanssen S, Norum J. Bladder and rectal toxicity of BeamCath application in radiotherapy of prostate cancer. Anticancer Research 28 (5B):2865 -8. 2008. | 19031926
Herstein A, Wallner K, Merrick G et al. I-125 versus Pd-103 for low-risk prostate cancer: long-term morbidity outcomes from a prospective randomized multicenter controlled trial. Cancer J. 2005; 11:385-389. | 16259869
Jabbari S, Weinberg VK, Shinohara K et al. Equivalent biochemical control and improved prostate-specific antigen nadir after permanent prostate seed implant brachytherapy versus high-dose three-dimensional conformal radiotherapy and high-dose conformal proton beam radiotherapy boost. International Journal of Radiation Oncology, Biology, Physics 76 (1):36 -42. 2010. | 19409729
Jani AB, Su A, Milano MT. Intensity-modulated versus conventional pelvic radiotherapy for prostate cancer: analysis of acute toxicity. Urology 67 (1):147 -51. 2006. | 16413351
Jani AB, Gratzle J, Correa D. Influence of intensity-modulated radiotherapy on acute genitourinary and gastrointestinal toxicity in the treatment of localized prostate cancer. Technology in Cancer Research & Treatment 6 (1):11-5. 2007. | 17241095
Jemal A, Siegel R, Ward E, Hao Y, Xu J, Thun MJ. Cancer statistics, 2009. CA: a Cancer Journal for Clinicians 59 (4):225 -49. 2009. | 19474385
Johansson JE, Andren O, Andersson SO et al. Natural history of early, localized prostate cancer. JAMA. 2004; 291:2713-2719. | 15187052
Joseph KJ, Alvi R, Skarsgard D et al. Analysis of health related quality of life (HRQoL) of patients with clinically localized prostate cancer, one year after treatment with external beam radiotherapy (EBRT) alone versus EBRT and high dose rate brachytherapy (HDRBT). Radiation Oncology 3:20. 2008. | 18627617
Katz AJ, Santoro M, Ashley R, Diblasio F, Witten M. Stereotactic body radiotherapy for organ-confined prostate cancer. BMC Urol. 2010; 10:1. | 20122161
Kuban DA TSD. Long-term results of the M. D. Anderson randomized dose-escalation trial for prostate cancer. International Journal of Radiation Oncology, Biology , Physics 70 (1):67 -74. 2008. | 17765406
Kupelian PA, Ciezki J, Reddy CA, Klein EA, Mahadevan A. Effect of increasing radiation doses on local and distant failures in patients with localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics 71 (1):16 -22. 2008. | 17996382
Langen KM, Willoughby TR, Meeks SL et al. Observations on real-time prostate gland motion using electromagnetic tracking. International Journal of Radiation Oncology, Biology, Physics 71 (4):1084 -90. 2008. | 18280057
Lawton CA, Michalski J, El-Naqa I et al. Variation in the definition of clinical target volumes for pelvic nodal conformal radiation therapy for prostate cancer. International Journal of Radiation Oncology, Biology, Physics 74 (2):377 -82. 2009. | 18947941
Leborgne F, Fowler J. Acute toxicity after hypofractionated conformal radiotherapy for localized prostate cancer: nonrandomized contemporary comparison with standard fractionation. International Journal of Radiation Oncology, Biology, Physics 72 (3):770-6. 2008. | 18375075
Leborgne F, Fowler J. Late outcomes following hypofractionated conformal radiotherapy vs. standard fractionation for localized prostate cancer: a nonrandomized contemporary comparison. International Journal of Radiation Oncology, Biology, Physics 74 (5):1441 -6. 2009. | 19395194
Lesperance RN, Kjorstadt RJ, Halligan JB, Steele SR. Colorectal complications of external beam radiation versus brachytherapy for prostate cancer. Am J Surg. 2008 May; 195(5):616-20; discussion 620. Epub 2008 Apr 2. | 18374892
Lev EL, Eller LS, Gejerman G et al. Quality of life of men treated for localized prostate cancer: outcomes at 6 and 12 months. Supportive Care in Cancer 17(5):509 -17. 2009. | 18719947
Lin C, Turner S, Mai T, Kneebone A, Gebski V. Late rectal and urinary toxicity from conformal, dose-escalated radiation therapy for prostate cancer: a prospective study of 402 patients. Australasian Radiology 51 (6):578-83. 2007. | 17958696
Litwin MS, Gore JL, Kwan L et al. Quality of life after surgery, external beam irradiation, or brachytherapy for early-stage prostate cancer. Cancer 109 (11):2239 -47. 2007. | 17455209
Lukka H, Hayter C, Julian JA et al. Randomized trial comparing two fractionation schedules for patients with localized prostate cancer. J Clin Oncol. 2005; 23: 6132-6138. | 16135479
Martinez AA, Demanes J, Vargas C, Schour L, Ghilezan M, Gustafson GS. High-Dose-Rate Prostate Brachytherapy: An Excellent Accelerated-Hypofractionated Treatment for Favorable Prostate Cancer. Am J Clin Oncol. 2009 Nov 30. [Epub ahead of print] | 19952715
Merrick GS, Butler WM, Wallner KE et al. Dosimetry of an extracapsular anulus following permanent prostate brachytherapy. American Journal of Clinical Oncology 30 (3):228 -33. 2007. | 17551297
Michalski JM, Bae K, Roach M et al. Long-term toxicity following 3D conformal radiation therapy for prostate cancer from the RTOG 9406 phase I/II dose escalation study. International Journal of Radiation Oncology, Biology, Physics 76 (1):14-22. 2010. | 19577865
Nakamura K, Shioyama Y, Tokumaru S et al. Variation of clinical target volume definition among Japanese radiation oncologists in external beam radiotherapy for prostate cancer. Japanese Journal of Clinical Oncology 38 (4):275 -80. 2008. | 18337319
Nieder AM, Porter MP, Soloway MS. Radiation therapy for prostate cancer increases subsequent risk of bladder and rectal cancer: a population based cohort study. Journal of Urology 180 (5):2005 -9. 2008. | 18801517
Norkus D, Miller A, Plieskiene A, Janulionis E, Valuckas KP. A randomized trial comparing hypofractionated and conventionally fractionated three-dimensional conformal external-beam radiotherapy for localized prostate adenocarcinoma: a report on the first-year biochemical response. Medicina (Kaunas, Lithuania) 45 (6):469 -75. 2009. | 19605967
Pe ML, Trabulsi EJ, Kedika R et al. Effect of percentage of positive prostate biopsy cores on biochemical outcome in low-risk PCa treated with brachytherapy or 3D-CRT.[see comment]. Urology 73 (6):1328 -34. 2009. | 19376564
Peeters ST HWKPvPWS. Dose-response in radiotherapy for localized prostate cancer: results of the Dutch multicenter randomized phase III trial comparing 68 Gy of radiotherapy with 78 Gy. Journal of clinical oncology: official journal of the American Society of Clinical Oncology 24 (13):1990-6. 2006. | 16648499
Pickles T, Keyes M, Morris WJ. Brachytherapy or conformal external radiotherapy for prostate cancer: a single-institution matched-pair analysis. International Journal of Radiation Oncology, Biology, Physics 76 (1):43 -9. 2010. | 19570619
Pollack A, Zagars GK, Starkschall G et al. Prostate cancer radiation dose response: results of the M. D. Anderson phase III randomized trial. Int J Radiat Oncol Biol Phys. 2002; 53:1097-1105. | 12128107
Pollack A, Hanlon AL, Horwitz EM et al. Dosimetry and preliminary acute toxicity in the first 100 men treated for prostate cancer on a randomized hypofractionation dose escalation trial. International Journal of Radiation Oncology, Biology, Physics 64 (2):518 -26. 2006. | 16242256
Prada PJ, Fernandez J, Martinez AA et al. Transperineal injection of hyaluronic acid in anterior perirectal fat to decrease rectal toxicity from radiation delivered with intensity modulated brachytherapy or EBRT for prostate cancer patients.[see comment]. International Journal of Radiation Oncology, Biology, Physics 69 (1):95 -102. 2007. | 17707267
Rose AJ, Backus BM, Gershman ST, Santos P, Ash AS, Battaglia TA. Predictors of aggressive therapy for nonmetastatic prostate carcinoma in Massachusetts from 1998 to 2002. Medical Care 45 (5):440 -7. 2007. | 17446830
Sakr WA, Haas GP, Cassin BF, Pontes JE, Crissman JD. The frequency of carcinoma and intraepithelial neoplasia of the prostate in young male patients. Journal of Urology 150 (2 Pt 1):379 -85. 1993. | 8326560
Sanda MG, Dunn RL, Michalski J et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. [see comment]. New England Journal of Medicine 358 (12):1250-61. 2008. | 18354103
Sathya JR, Davis IR, Julian JA et al. Randomized trial comparing iridium implant plus external-beam radiation therapy with external-beam radiation therapy alone in node-negative locally advanced cancer of the prostate. J Clin Oncol. 2005; 23 :1192-1199. | 15718316
Song Y, Chan MF, Burman C, Cann D. Comparison of two treatment approaches for prostate cancer: intensity-modulated radiation therapy combined with 125I seed-implant brachytherapy or 125I seed-implant brachytherapy alone. Journal of Applied Clinical Medical Physics 9 (2):2283. 2008. | 18714275
Soto DE, Glaser S, Roberts RH et al. Impact of common iliac nodal treatment on radiation outcomes in localized prostate cancer. Urology 71 (2):313 -7. 2008. | 18308110
Soumarova R, Homola L, Perkova H, Stursa M. Three-dimensional conformal external beam radiotherapy versus the combination of external radiotherapy with high-dose rate brachytherapy in localized carcinoma of the prostate: comparison of acute toxicity. Tumori 93 (1):37-44. 2007. | 17455870
Stone NN, Potters L, Davis BJ et al. Customized dose prescription for permanent prostate brachytherapy: insights from a multicenter analysis of dosimetry outcomes.[see comment]. International Journal of Radiation Oncology, Biology, Physics 69 (5):1472 -7. 2007. | 17689026
Stone NN, Potters L, Davis BJ et al. Multicenter analysis of effect of high biologic effective dose on biochemical failure and survival outcomes in patients with Gleason score 7-10 prostate cancer treated with permanent prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics 73 (2):341 -6. 2009. | 18597953
Tewari A, Divine G, Chang P et al. Long-term survival in men with high grade prostate cancer: a comparison between conservative treatment, radiation therapy and radical prostatectomy--a propensity scoring approach.[erratum appears in J Urol. 2007 May;177(5):1958]. Journal of Urology 177 (3):911-5. 2007. | 17296374
van Lin EN, Kristinsson J, Philippens ME et al. Reduced late rectal mucosal changes after prostate three-dimensional conformal radiotherapy with endorectal balloon as observed in repeated endoscopy. International Journal of Radiation Oncology, Biology, Physics 67 (3):799 -811. 2007. | 17161552
Vora SA, Wong WW, Schild SE, Ezzell GA, Halyard MY. Analysis of biochemical control and prognostic factors in patients treated with either low-dose three-dimensional conformal radiation therapy or high-dose intensity-modulated radiotherapy for localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics 68 (4):1053 -8. 2007. | 17398023
Wallner K, Merrick G, True L, Sutlief S, Cavanagh W, Butler W. 125I versus 103Pd for low-risk prostate cancer: preliminary PSA outcomes from a prospective randomized multicenter trial. Int J Radiat Oncol Biol Phys. 2003; 57:1297-1303. | 14630265
Wallner K, Merrick G, True L et al. 20 Gy versus 44 Gy supplemental beam radiation with Pd-103 prostate brachytherapy: preliminary biochemical outcomes from a prospective randomized multi-center trial. Radiother Oncol. 2005; 75: 307-310. | 16086912
Williams SG, Taylor JM, Liu N et al. Use of individual fraction size data from 3756 patients to directly determine the alpha/beta ratio of prostate cancer. International Journal of Radiation Oncology, Biology, Physics 68 (1):24-33. 2007. | 17448868
Wong WW, Vora SA, Schild SE et al. Radiation dose escalation for localized prostate cancer: intensity-modulated radiotherapy versus permanent transperineal brachytherapy. Cancer 115 (23):5596 -606. 2009. | 19670452
Yeoh EE, Holloway RH, Fraser RJ et al. Hypofractionated versus conventionally fractionated radiation therapy for prostate carcinoma: updated results of a phase III randomized trial. Int J Radiat Oncol Biol Phys. 2006; 66:1072-1083. | 16965866
Yeoh EK, Holloway RH, Fraser RJ et al. Anorectal function after three- versus two-dimensional radiation therapy for carcinoma of the prostate. International Journal of Radiation Oncology, Biology, Physics 73 (1):46 -52. 2009. | 18571336
Zelefsky MJ, Nedelka MA, Arican ZL et al. Combined brachytherapy with external beam radiotherapy for localized prostate cancer: reduced morbidity with an intraoperative brachytherapy planning technique and supplemental intensity-modulated radiation therapy. Brachytherapy 7 (1):1-6. 2008. | 18299108
Zelefsky MJ, Yamada Y, Fuks Z et al. Long-term results of conformal radiotherapy for prostate cancer: impact of dose escalation on biochemical tumor control and distant metastases-free survival outcomes. International Journal of Radiation Oncology, Biology, Physics 71 (4):1028 -33. 2008. | 18280056
Zelefsky MJ, Levin EJ, Hunt M et al. Incidence of late rectal and urinary toxicities after three-dimensional conformal radiotherapy and intensity-modulated radiotherapy for localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics 70 (4):1124 -9. 2008. | 18313526
Zhou EH, Ellis RJ, Cherullo E et al. Radiotherapy and survival in prostate cancer patients: a population-based study. International Journal of Radiation Oncology, Biology, Physics 73 (1):15 -23. 2009. | 18538495
Zietman AL, DeSilvio ML, Slater JD et al. Comparison of conventional-dose vs high-dose conformal radiation therapy in clinically localized adenocarcinoma of the prostate: a randomized controlled trial. JAMA. 2005; 294:1233-1239. | 16160131
Zietman AL, Bae K, Slater JD et al. Randomized trial comparing conventional-dose with high-dose conformal radiation therapy in early-stage adenocarcinoma of the prostate: long-term results from proton radiation oncology group/american college of radiology 95-09. J Clin Oncol. 2010; 28:1106-1111. | 20124169