# CyberKnife® and related studies

We searched MEDLINE® on 1/12/2010 specifically for studies on prostate cancer treatment with CyberKnife®. We identified 15 studies, only one qualified for inclusion in our review. We also searched clinicaltrials.gov on 2/9/2010 and identified seven studies on CyberKnife® and prostate cancer registered on the clinicaltrials.gov website, one of them has been completed (NCT00855647) but the study results have not yet been publicly posted (http://clinicaltrials.gov/ct2/results?term=CyberKnife&pg=2).

Table H1 Studies on prostate cancer treatment with CyberKnife® (MEDLINE® on 1/12/2010)

Study | Title & Reference | Reason for exclusion
Fuller 2008 18374232 | Virtual HDR CyberKnife treatment for localized prostatic carcinoma: dosimetry comparison with HDR brachytherapy and preliminary clinical observations. International Journal of Radiation Oncology, Biology, Physics. 2008;70:1588–1597 | No comparative clinical outcome
Hossain 2008 18841856 | Simulated real time image guided intrafraction tracking-delivery for hypofractionated prostate IMRT. Medical Physics. 2008;35:4041–4048 | No clinical outcome
King CR 2003 12625751 | CyberKnife radiotherapy for localized prostate cancer: rationale and technical feasibility. Technology in Cancer Research & Treatment. 2003;2:25–30 | No clinical outcome
Pawlicki 2007 17472885 | Investigation of linac-based image-guided hypofractionated prostate radiotherapy. Medical Dosimetry. 2007;32-71-79 | No clinical outcome
Xie 2008 18722274 | Intrafractional motion of the prostate during hypofractionated radiotherapy. International Journal of Radiation Oncology, Biology, Physics. 2008;72:236–246 | No clinical outcome
Friedland 2009 19754215 | Stereotactic body radiotherapy: an emerging treatment approach for localized prostate cancer. Technology in Cancer Research & Treatment. 2009;8:387–392 | Single cohort study
King 2009 18755555 | Stereotactic body radiotherapy for localized prostate cancer. Interim results of a prospective phase II clinical trial. International Journal of Radiation Oncology, Biology, Physics. 2009;73:1043–1048 | Single cohort study (likely related to NCT00855647 listed above)
de CR 2006 17035061 | Prostate localization systems for prostate radiotherapy. [Review][French] Cancer Radiotherapie. 2006:10:394–401 | Review
de CR 2009 19211367 | Image-guided radiotherapy: rational, modalities and results. [French] Bulletin du Cancer. 2009; 96:123–132 | Review
Pawlicki 2007 17641522 | Prostate cancer therapy with stereotactic body radiation therapy. [Review] Frontiers of Radiation Therapy & Oncology. 2007;40:395–406 | Review
Thariat 2009 19736172 | Current indications and ongoing clinical trials with CyberKnife stereotactic radiotherapy in 2009. [French] Bulletin du Cancer 2009; 96:853–864 | Review
King 2009 19147028 | Testicular dose from prostate CyberKnife: a cautionary note. International Journal of Radiation Oncology, Biology, Physics. 2009;73:636–637 | Commentary
Vikram 2009 19735890 | In regard to King et al. (Int J Radiat Oncol boil Phys 2009;73:1043–1048). International Journal of Radiation Oncology, Biology, Physics. 2009;75:632 | Commentary
Yeager 2009 19147032 | Accuray company advertising successful prostate cancer treatments with CyberKnife. International Journal of Radiation Oncology, Biology, Physics. 2009;73:638–639 | Commentary
Hannoun-Levi 2007 17888705 | Robotic radiotherapy for prostate cancer with CyberKnife [French]. Cancer Radiotherapie. 2007;11:476–482 | Discussion

Table H2 Additional studies from 2007–2009 on stereotactic body radiation therapy for prostate cancer identified from MEDLINE® 12/30/2010 that did not quality for inclusion in this review

Study | Title & Reference | Reason for exclusion
Madsen 2007 17336216 | Stereotactic hypofractionated accurate radiotherapy of the prostate (SHARP), 33.5 Gy in five fractions for localized disease: first clinical trial results. International Journal of Radiation Oncology, Biology, Physics. 67(4):1099–105, 2007 Mar 15. | Single cohort study
Chang 2007 18091059 | Stereotactic body radiation therapy: a comprehensive review. American Journal of Clinical Oncology. 30(6):637–44, 2007 Dec. | Review
Lo 2010 19997074 | Stereotactic body radiation therapy: a novel treatment modality. Nature Reviews Clinical Oncology. 7(1):44–54, 2010 Jan. | Review

Table H3 Additional studies from 2007–2009 on High Dose Rate Brachytherapy for prostate cancer identified from MEDLINE® 12/30/2010 that did not quality for inclusion in this review

Study | Title & Reference | Reason for exclusion
Kim 2007 18449148 | Measurement of craniocaudal catheter displacement between fractions in computed tomography-based high dose rate brachytherapy of prostate cancer. Journal of Applied Clinical Medical Physics 8 (4):2415. 2007. | No clinical outcome
Morton 2008 18037356 | A comparison of anatomy-based inverse planning with simulated annealing and graphical optimization for high-dose-rate prostate brachytherapy, Brachytherapy 7 (1):12–6. 2008;-Mar. | No clinical outcome
Nilsson 2008 17980507 | Is the use of a surrogate urethra an option in prostate high-dose-rate brachytherapy? International Journal of Radiation Oncology, Biology, Physics 71 (1):36–40. 2008. | No clinical outcome
Das 2007 18044301 | Thermoluminescence dosimetry for in-vivo verification of high dose rate brachytherapy for prostate cancer. Australasian Physical & Engineering Sciences in Medicine 30 (3):178–84. 2007. | Single cohort study
Ghadjar 2009 19038584 | Toxicity and early treatment outcomes in low- and intermediate-risk prostate cancer managed by high-dose-rate brachytherapy as a monotherapy. Brachytherapy 8 (1):45–51. 2009;-Mar. | Single cohort study
Konishi 2009 19345517 | Correlation between dosimetric parameters and late rectal and urinary toxicities in patients treated with high-dose-rate brachytherapy used as monotherapy for prostate cancer. International Journal of Radiation Oncology, Biology, Physics 75 (4):1003–7. 2009. | Single cohort study
Yoshida 2007 17606414 | New implant technique for separation of the seminal vesicle and rectal mucosa for high-dose-rate prostate brachytherapy. Brachytherapy 6 (3):180–6. 2007;-Sep. | Single cohort study
Corner 2008 18249501 | A Phase II study of high-dose-rate afterloading brachytherapy as monotherapy for the treatment of localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics 72 (2):441–6. 2008. | Did not meet our inclusion criteria
Hoskin 2008 18755623 | [Review] [9 refs]. Cancer Radiotherapie 12 (6–7):512–4. 2008. | Review