# Detailed results for Key Question 3

## Key Question 3 How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbidities, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression) affect the outcomes of these different forms of radiation therapy?

For this question, we evaluated only direct comparisons within studies. We did not make indirect cross-study comparisons. Patient-level characteristics are those that describe a patient’s pre-procedure physical characteristics, prostate cancer characteristics, and other comorbid conditions.

### Baseline risk

(Table G1)

One long-term follow-up of an RCT32 and four retrospective cohort studies15, 22, 40, 54 evaluated different baseline risk as a potential modifying factor. Three studies categorized patients according to the National Comprehensive Cancer Network (NCCN) Guidelines risk stratification32, 40, 54 and two were based on D’Amico stratification.15, 22, 72 No consistent pattern of effect modification by baseline risk category was observed in these studies.

In the long-term follow-up of an RCT, the rate of 8-year freedom from clinical and/or biochemical failure was higher in the 78 Gy group than the 70 Gy group among low-risk (88% vs. 63%; P = 0.042) and high-risk patients (63% vs. 26%; P = 0.004), but no significant difference was noted in the intermediate-risk patients (86% vs. 76%; P = 0.36).32

In a retrospective cohort study with 16 years of follow-up, PSA relapse-free survival rates did not differ between radiation dosage groups (70.2, 75.6, 81, 86.4 Gy) among low-risk patients (quantitative data not provided); the rates were higher in the 75.6 Gy or 81 Gy group than 70.2 Gy or 86.4 Gy groups (HR: 0.71; P < 0.0001) in the intermediate risk group.40 For high-risk patients, 5-year PSA relapse-free survival rates in 70.2 Gy, 75.6 Gy, 81 Gy, and 86.4 Gy groups were significantly different at 40%, 61%, 66%, and 71%, respectively (P < 0.0001). There were no differences in the rates of distant metastases free survival between different dosage groups among low-risk patients (quantitative data not provided); the rate was higher in the 81 Gy group than the 75.6 Gy groups among intermediate-risk patients (HR: 0.77; P = 0.04), and it was also higher in the 81 Gy group compared to the 70.2 Gy group among high-risk patients (HR: 0.83; P = 0.01).

A second retrospective cohort study reported that the five-year biochemical control rates did not differ among conventional dose 3D-CRT, high-dose IMRT, BT alone, and EBRT + BT groups among low- (92%, 93%, 97%, 100%, respectively; P = 0.298) and high-risk patients (55%, 76%, 50%, 100%, respectively; P = 0.184).22 However, biochemical control rates were significantly better in high-dose IMRT, BT alone, or EBRT + BT group than conventional dose 3D-CRT group among intermediate-risk patients who did not receive ADT (85%, 83%, 100% vs. 65%, respectively; P = 0.0003). None of the patients in these comparisons received ADTs.

Two retrospective cohort studies reported no difference in treatment outcomes among baseline risk categories. In the study that examined three biologically effective dosages of BT, rates of biochemical freedom from failure were significantly increased with increasing dosages (< 140 Gy, 140-200 Gy, > 200 Gy) in all risk categories (low risk: 49.8% vs. 85.2% vs. 88.3%; P < 0.0001; intermediate risk: 23.1% vs. 77.7% vs. 88.8%; P < 0.0001; high risk: 41.7% vs. 53.2% vs. 69.6; P < 0.0001). 54 In the other study, 10-year disease specific survival rates were higher in the EBRT group than the observation group, although statistical significance was not reported (low risk: 93% vs. 90%; intermediate risk: 88% vs. 81%; high risk: 80% vs. 70%; P value not reported).15

### Gleason Score

One retrospective study found that across three dosages of BT (< 200 Gy, 200-220 Gy, > 220 Gy), rates of biochemical freedom from failure were significantly different among patients with baseline Gleason score of 8-10 (51.6% vs. 85.5%, vs. 90%; P < 0.001), but not among patients with Gleason score of 7 (82.3% vs. 82.5% vs. 89.5%; P = 0.09).55

### Baseline PSA concentration

One long-term follow-up study of an RCT found a greater difference in the 8-year freedom from clinical and/or biochemical failure rate between the 78 Gy and the 70 Gy groups among patients with baseline PSA >10 ng/mL (78% vs. 39%; P < 0.001) than in patients with baseline PSA ≤ 10 ng/mL (78% vs. 66%; P = 0.24).32 Among patients with baseline PSA >10 ng/ml, the rate of freedom from distant metastasis was higher in the 78 Gy group compared with the 70 Gy group, but statistical significance was not reached (98% vs. 88%; P = 0.056).33 Among patients with baseline PSA ≤ 10 ng/ml, one patient in the 78 Gy group had distant metastasis while no patient in the 70 Gy group did (quantitative data not reported).33

### Interaction of baseline risk category and PSA concentration

The interaction of baseline risk category and PSA concentrations was also evaluated in the above study. 32 Among intermediate- or high-risk patients, rates of freedom from clinical and/or biochemical failure at 8 years were significantly different between 78 Gy and 70 Gy among patients with baseline PSA >10 ng/mL, but not different among patients with baseline PSA ≤ 10 ng/mL (quantitative data not provided); no such difference was observed among low-risk patients.

Table G1 Effects of patient characteristics on treatment outcomes of different radiation therapies

Author Year [UI] | Treatment comparison | Analysis by factor of interest | Quality
Baseline risk on biochemical failure
Albertsen 2007 [17296379] | EBRT vs. observation | Low risk – ▲survival rate in EBRT (P value not reported) Intermediate risk – ▲survival rate in EBRT (P value not reported) High risk - ▲survival rate in EBRT (P value not reported) | B
Kuban 2008 [17765406] | 3D-CRT 78 Gy vs. 70 Gy | Low risk – ▲FFF in 78 Gy (P = 0.042) Intermediate risk – no difference High risk – ▲FFF in 78 Gy (P = 0.004) | B
Stone 2007 [17689026] | BT < 140 Gy, 140-200 Gy, > 200 Gy | Low risk - ▲FFF in higher dose (P < 0.0001) Intermediate risk - ▲FFF in higher dose (P < 0.0001) High risk - ▲FFF in higher dose (P < 0.0001) | B
Wong 2009 [19670452] | conventional dose 3D-CRT, high-dose IMRT, BT alone, or EBRT + BT | Low risk – no difference Intermediate risk – FFF: conventional dose 3D-CRT< BT alone < high-dose IMRT < EBRT + BT (P = 0.0003) High risk – no difference | B
Zelefsky 2008 [18280056] (452) | 3D-CRT or IMRT 70.2, 75.6, 81, 86.4 Gy | Low risk– no difference Intermediate risk– ▲ PSA-relapse free survival in the 75.6 Gy or 81 Gy group compared with 70.2 Gy or 86.4 Gy groups (P < 0.0001); ▲rate of distant metastases free survival in 81 Gy compared with 75.6 Gy (P = 0.04) High risk– ▲ PSA-relapse free survival with ▲dose (P < 0.0001); ▲rate of distant metastases free survival in 81 Gy compared with 70.2 Gy (P = 0.01) | B
Baseline PSA concentration
Kuban 2008 [17765406] Pollack 2002 [2128107] | 3D-CRT 78 Gy vs. 70 Gy | PSA >10 ng/ml – ▲FFF in 78 Gy (P < 0.001); no difference in rate of distant metastases free survival PSA ≤ 10 ng/ml – no difference | B
Gleason Score
Stone 2009 [18597953] | BT < 200 Gy, 200-220 Gy, >220 Gy | score 7 – no difference score 8-10 - ▲FFF with ▲dose (P < 0.001) | B
Interaction between baseline risk category and baseline PSA concentration
Kuban 2008 [17765406] Pollack 2002 [2128107] | 3D-CRT 78 Gy vs. 70 Gy | The difference in treatment between patients with PSA >10 ng/ml and patients with PSA <10 ng/ml was present among intermediate- and high-risk patients, but not among low-risk patients. | B

FFF: freedom from failure rate