# Detailed results for intra-LDRBT comparisons

## Intra-LDRBT comparisons

(Tables F1–F3)

### Randomized controlled trials (RCTs)

(Table F1, F3)

One RCT compared I-125 (144 Gy) with Pd-103 (125 Gy) and reported three interim analyses on long-term morbidity and biochemical outcomes.51–53 The number of patients reported in these three interim analyses ranged from 115 to 314. All the patients had either T1 or T2 disease. Less than 20 percent of the patients received some form of ADTs. Comparing I-125 with Pd-103, this trial reported that the freedom from biochemical failure at 3 years was 89% versus 91% (P = 0.76), and at 6 years it was 97% versus 99% (P = 0.15), respectively. This trial reported no significant difference between the two groups in the American Urological Association (AUA) Symptom Index at 2 years. This trial also noted a non-significant trend in more persistent rectal bleeding in the I-125 patients compared to the Pd-103 patients. The methodological quality of all 3 reports were rated B. Neither the patient nor the treating physician was blinded to the isotope used in the trial.

A second RCT compared LDRBT using I-125 (145 Gy) with LDRBT using I-125 (145 Gy) plus rectal protection with injection of hyaluronic acid.56 All 69 patients had T1 or T2 disease. Up to 45% of the patients received some form of ADTs. Patients treated with rectal protection using hyaluronic acid had no macroscopic rectal bleeding, while 12% of patients without rectal protection had macroscopic rectal bleeding (P = 0.047). This was presumably assessed via patient questionnaire at the time of follow-up endoscopy (ranged from 13 to 24 months postimplant). The authors further stated that “no toxicity was produced from the hyaluronic acid or its injection”. This study was rated B. No information was provided on the method of randomization.

### Retrospective studies

(Table F2)

Two retrospective analyses of the same sample reported the combined experience from 6 centers comparing different biological effective dose (BED) using I-125 or Pd-103 in which supplemental EBRT (22% of the patients) and short-term ADT was used (39%).54, 55 The total sample size was 3,928. One percent of the patients had T3 disease. The BED being compared were <140 Gy, 140–200 Gy, and >200 Gy; the 10-year biochemical freedom from failure were 41%, 78%, 83% (P<0.0001, one way ANOVA), respectively. The study also analyzed 5-year biochemical freedom from failure by stratifying the BED dose into ≤ 220 Gy vs. > 220 Gy: in those patients with Gleason score 7, the rate was 84.2% vs. 89.5% (P = 0.073), respectively; in those with Gleason score 8 to 10, the rate was 48.8% vs. 85.7% (P = 0.05), respectively. The study also reported that in patients with PSA level > 20 ng/mL, a greater BED resulted in improved 5-year biochemical freedom from failure in the Gleason score 7 to 10 and 8 to 10 groups. Among patients with Gleason score 8–10, 5-year overall survival rate was significantly different across BED < 200 Gy, 200–220 Gy, and > 220 Gy groups (86.6% vs. 89.4% vs. 94.6%; P < 0.048). The methodological quality of this study was rated B. There was potential selection bias in this study as only those patients with dosimetry results (67%) were included.

Table F1 Characteristics of randomized controlled trials that compared different brachytherapy techniques

Author Year [UI] Country | Intervention(s) or comparison | N | Mean age, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Herstein 2005 [16259869] US | LDRBT (I^125^) | 159 | 65 | nd | 100 | 7: (1.9) | Range: 2–6 | 18 | 144Gy, TG 43 | nd | nd | nd | nd | B com-8
Herstein 2005 [16259869] US | LDRBT (Pd^103^) | 155 | 66 | nd | 100 | 6.7: (1.7) | Range: 2–6 | 17 | 125 Gy, NIST 99 | nd | nd | nd | nd
Merrick 2007 [17551297] US | LDRBT (I^125^) | 127 | 64 | nd | 100 | 6.4: (1.7) | 5.9: (0.3) A | Yes, nd% | 125 Gy, TG 43 | nd | nd | 0.5 cm | AAPM TG-43 and update | B com-2, 8
Merrick 2007 [17551297] US | LDRBT (Pd^103^) | 136 | 65 | nd | 100 | 6.7: (1.9) | 6.0: (0.3) A | Yes, nd% | 145 Gy, ABS-2000 | nd | nd | 0.5 cm | same as above
Prada 2009 [19213607] 2009 | LDRBT (I^125^) with 6–8cc of hyaluronic acid | 36 | 68 | nd | 100 | 8: (nd) | ≤6: 97% 7: 3% | 44 | 145 Gy, TG 43 | nd | nd | nd | nd | C com-2, 8
Prada 2009 [19213607] 2009 | LDRBT (I^125^) | 33 | 69 | nd | 100 | 8: (nd) | ≤6: 92% 7: 8% | 45 | 145 Gy, TG 43 | nd | nd | nd | nd
Wallner 2003 [14630265] US | LDRBT (I^125^) | 57 | 65 | nd | 100 | 7.0: (1.9) | 5.9: (0.24)^A^ | 16 | 144Gy, TG 43 | nd | nd | nd | nd | B
Wallner 2003 [14630265] US | LDRBT (Pd^103^) | 58 | 66 | nd | 100 | 6.7: (1.7) | 5.9: (0.29)^A^ | 19 | 125 Gy, NIST 99 | nd | nd | nd | nd

A mean (SD)

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table F2 Characteristics of retrospective cohort studies that compared different brachytherapy techniques

Author Year [UI] Country | Intervention(s) or comparison | N | Mean age, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Stone 2007 2009 [17689026, 18597953] US | biological effective dose (BED) <140 140–200, or >200 Gy C | 3928 | nd | nd | 99 | ≤10: 76 10–20: 19: >20 5 | ≤6 73 7 22 8–10 6 | 62 | nd | nd | nd | nd | nd | B

C 58% of patients had supplemental EBRT

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table F3 Urinary dysfunction: intra-LDRBT

Author Year [UI] Country | Outcome | Intervention | Follow-up, yr | No. Analyzed | Baseline | Change (SD) | Net difference | 95%CI | P btw | Quality
Herstein 2005 [16259869] US | AUA score | LDRBT (I^125^) | 2 | 151 | 7.6 | 1.2 (7.31) | +0.50 | −1.16, 2.16 | 0.89 | B
Herstein 2005 [16259869] US | AUA score | LDRBT (Pd^103^) | | 145 | 8.2 | 0.7 (7.22)

AUA score, AUA symptom index, American Urological Association symptom index (range, 0–35) in which higher scores indicate worse outcomes

This study was a RCT from Minnesota report.