# Detailed results for intra-SBRT and intra-EBRT comparisons

## Intra-SBRT comparisons

No RCTs or prospective cohort studies compared different SBRT doses or techniques. One retrospective study with a median follow-up of 30 months compared the use of 35 Gy in 5 fractions of 7 Gy (N = 50; first 50 patients) versus 36.25 Gy in 5 fractions of 7.25 Gy (N = 254) to treat patients with clinically localized prostate cancer (all T1 or T2).31 Acute RTOG grade 2 bladder and rectal toxicities were comparable in the two groups (bladder 4% vs. 4.7%; rectal 4% vs. 3.6%, respectively). Late RTOG grade 3 bladder and rectal toxicities were also comparable (bladder 0% vs. 0.5%; rectal 0% vs. 0%). In those patients who did not receive ADT and had a minimum follow-up of 12 months, no biochemical failure occurred in the 35 Gy group (denominator not reported); four biochemical failures occurred in the 36.25 Gy group (denominator not reported). This study was rated C because of historical comparison and incomplete analysis and reporting.

## Intra-EBRT Comparisons

Eight RCTs, 3 prospective cohorts, and 13 retrospective cohorts reported intra-EBRT comparisons based on different radiation dosages, fractions or modalities. We grouped these studies based on these comparisons.

## EBRT Dose Comparisons

(Tables E1–E3; Figures E1–E3)

### Randomized controlled trials (RCTs)

(Table E1)

Three RCTs reported in 5 publications compared conventional dose EBRT with high dose EBRT.32–36 The sample size in these studies ranged from 301 to 664. One study included only patients with T1 or T2 disease,35 while the other two studies included some patients with T3 or higher stage disease. Two studies did not include patients who received ADTs,32, 33, 35 while the third trial included about 20% of patients who also received some form of ADTs. Of note, one trial used a proton therapy boost after initial photo therapy treatment.35 The methodological quality of all 3 RCTs were rated B. A common reason for downgrading the quality ratings in these studies was suboptimal reporting (e.g., unclear descriptions on the conduct of a trial or discrepancies in reporting of results).

#### Freedom from biochemical failure

(Figure E1)

Two RCTs reported that the freedom from biochemical or clinical failure at 5 years was significantly increased for patients treated with higher dose compared to those treated with lower dose (91% vs. 79%; P <0.001^35^ and 85% vs. 78%; P = 0.004.^32, 33^) The other trial reported a non-significant difference between the 2 groups in a subset analysis of low/intermediate risk patients (low dose 73.3% vs. high dose 81.4%).34

#### Genitourinary toxicity

(Table E2)

One RCT provided data on genitourinary toxicity.35 Comparing high with low dose, the incidence rates of acute genitourinary toxicity grade 3 or greater were 1.5% versus 1% (P = NS) and the rates for late genitourinary toxicity were 0.5% versus 1.5%, respectively.

#### Gastrointestinal toxicity

(Table E3)

The same RCT also provided data on gastrointestinal toxicity. Comparing high with low dose, the incidence rates of acute gastrointestinal toxicity grade 3 or greater were 0% versus 1% (P = NS) and the rates for late gastrointestinal toxicity were 0.5% versus 0.5%, respectively.

### Prospective studies

(Table E1)

Two prospective cohorts reported dose comparisons with sample sizes ranged from 402 to 956. 41, 68 One study enrolled only patients with T1 or T2 disease and both of them had up to 40% of the patients receiving some form of ADTs. First study divided patients into three groups based on clinical stage.41 Group 1 patients had clinical Stage T1 disease with minimal risk of seminal vesicle invasion. Group 2 patients had a risk of seminal vesicle invasion more than 15%. Group 3 patients had clinical Stage T3 disease. Each group was then divided into five levels and treated with different radiation doses. This review excluded group 3 because this group included patients with stage T3 disease. The incidence rates of late grade 3 or greater genitourinary toxicity were 1%, 4%, 5%, 3%, and 5% for group 1 and 3%, 2%, 3%, 6%, and 6% for group 2 at dose levels of I through V. The incidence rates for late grade 3 or greater gastrointestinal toxicity were 1%, 0%, 1%, 3%, and 4% for group 1 and 3%, 0%, 3%, 2%, and 7% for group 2 at dose levels of I through V. No further statistical analysis was provided because these rates were not large enough to be modeled. The methodological quality of this study was rated B.

Second study only provided analysis on late grade 2 or greater genitourinary toxicity, no separate analysis for late grade 3 or greater was provided. There was no significant difference between the two arms in late grade 2 or greater genitourinary toxicity (21% in 74 Gy arm vs. 17.3% in 70 Gy arm; P = 0.26).68 Similarly, the late grade 2 or greater gastrointestinal toxicity was also not significantly different between the two arms (9.2% in 74 Gy arm vs. 6.1% in 70 Gy arm; P = 0.31). The methodological quality of this study was rated C because there was no adjustment for potential confounders.

### Retrospective studies

(Table E1)

Nine retrospective cohorts in 10 publications reported dose comparisons with sample size ranged from 80 to 2,047.^22, 37–40, 42, 69–72^ All studies included patients with T3 or higher stage disease (5% to 20%) and only two studies did not include patients who received some form of ADTs.37, 39 In terms of the methodological quality, 6 studies were rated B and 3 were rated C. A common reason for downgrading these studies was suboptimal reporting.

#### Freedom from biochemical failure

(Figures E1–E2)

Five cohorts in six publications comparing different radiation doses reported freedom from biochemical failure at intervals ranging from 5 to 10 years.22, 37–40, 72 All of the studies consistently reported that higher radiation dose administered were associated with increased rates of freedom from biochemical failure.

#### Genitourinary toxicity

(Table E2)

Two studies reported acute genitourinary toxicity.22, 71, 72 The incidence rates of acute genitourinary toxicity grade 3 or greater were not significantly different between the arms in both studies. Four studies reported late genitourinary toxicity and the incidence rates of late genitourinary toxicity grade 3 or greater were also not significantly different between the arms in any of the studies.22, 38, 69, 71, 72

#### Gastrointestinal toxicity

(Table E3)

Two studies reported the incidence rates of acute gastrointestinal toxicity grade 3 or greater were not significantly different between the arms in both studies.22, 71, 72 Five studies reported the incidence rates of late gastrointestinal toxicity grade 3 or greater were not significantly different between the arms in any of the studies.22, 38, 42, 69, 71, 72

Table E1 Characteristics of studies that compared different EBRT doses

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Comments
RCT
Peeters 2006 16648499 Netherlands | EBRT (68 Gy) | 331 | 68.6 | nd | 63 | ≤4: 8 4–10: 29 10–20: 38 20–60: 26 | 2–4: 32 5–7: 51 8–10: 17 | 22 | 68 | 2 | nd | 1.0 cm | nd | B com-8
Peeters 2006 16648499 Netherlands | EBRT (78 Gy) | 333 | 68.8 | nd | 63 | ≤4: 6 4–10: 36 10–20: 38 20–60: 21 | 2–4: 28 5–7: 59 8–10: 14 | 21 | 78 | 2 | nd | 1.0 cm during the first 68 Gy, 0.5 cm for the last 10 Gy | nd
Pollack 2002 2128107 and Kuban 2008 17765406 USA | EBRT (3D-CRT (70 Gy) arm) | 150 | nd | nd | 83 | <10: 65 >10: 35 | 2–6: 46 7: 37 8–10: 17 | 0 | 70 | nd | nd | 1.25–1.5 cm anterior & inferior 0.75–1.0 cm posterior & superior | nd | B com-8
Pollack 2002 2128107 and Kuban 2008 17765406 USA | EBRT (3D-CRT (78 Gy) arm) | 151 | nd | nd | 77 | <10: 65 >10: 35 | 2–6: 50 7: 32 8–10: 18 | 0 | 78 | nd | nd | 1.25–1.5 cm anterior & inferior 0.75–1.0 cm posterior & superior | nd
Zietman 2005 16160131 and Zietman 2010 20124169 USA | EBRT (Conventional 70.2 GyE) | 197 | 67 | White: 89.3 Black: 6.1 Hispanic: 2 | 100 | <4: 12 4-<10: 74 10–15: 14 | 2–6: 75 7: 15 8–10: 9 | 0 | 70.2 GyE | 1.8 GyE | casts of thermal plastic or body foam with rectal balloon | 0.7–1.0 cm | nd | B com-2
Zietman 2005 16160131 and Zietman 2010 20124169 USA | EBRT (High 79.2 GyE) | 195 | 66 | White: 91.3 Black: 2.6 Hispanic: 3.6 | 100 | <4: 11 4-<10: 74 10–15: 15 | 2–6: 75 7: 15 8–10: 8 | 0 | 79.2 GyE | 1.8 GyE | casts of thermal plastic or body foam with rectal balloon | 0.7–1.0 cm | nd
Prospective Cohort Study
Lin 2007 17958696 Australia | EBRT (70 Gy 3D CRT) | 292 | 69 (overall) | nd | 90 | <10: 43.8 10–20: 36.8 >20: 19.4 | ≤6: 44 7: 39.1 8–10: 16.9 | 57.8 | 74 | 2 | nd | 1.0–1.5 cm (1.0 cm posteriorly) added for PTV1, 0.5–1.0 cm (<0.5 cm posteriorly) added for PTV 2 | nd | C com-2
Lin 2007 17958696 Australia | EBRT (74 Gy 3D CRT) | 110 | | | | | | | 70 | 2 | nd | | nd
Michalski 2010 19577865 USA | EBRT (3D-CRT) Level 1, Disease group 1 | 75 | | nd | 100 | ≤10: 75 20: 24 ≥20: 1 | 2–6: 93 7: 7 8–10: 0 | 8 | 68.4 | 1.8 | nd | 0.5–1.0 cm | nd | B com-2
| EBRT (3D-CRT) Level 1, Disease group 2 | 33 | | nd | 100 | ≤10: 42 20: 33 ≥20: 24 | 2–6: 36 7: 36 8–10: 27 | 15 | 68.4 | 1.8 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 2, Disease group 1 | 97 | | nd | 100 | ≤10: 81 20: 19 ≥20: 0 | 2–6: 95 7: 5 8–10: 0 | 20 | 73.8 | 1.8 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 2, Disease group 2 | 108 | | nd | 100 | ≤10: 43 20: 35 ≥20: 22 | 2–6: 41 7: 41 8–10: 19 | 48 | 73.8 | 1.8 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 3, Disease group 1 | 104 | | nd | 100 | ≤10: 87 20: 13 ≥20: 1 | 2–6: 94 7: 6 8–10: 0 | 30 | 79.2 | 1.8 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 3, Disease group 2 | 63 | | nd | 100 | ≤10: 43 20: 38 ≥20: 19 | 2–6: 22 7: 46 8–10: 32 | 68 | 79.2 | 1.8 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 4, Disease group 1 | 115 | | nd | 100 | ≤10: 86 20: 14 ≥20: 0 | 2–6: 91 7: 9 8–10: 0 | 22 | 74 | 2 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 4, Disease group 2 | 141 | | nd | 100 | ≤10: 50 20: 32 ≥20: 18 | 2–6: 21 7: 56 8–10: 23 | 52 | 74 | 2 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 5, Disease group 1 | 119 | | nd | 100 | ≤10: 77 20: 23 ≥20: 0 | 2–6: 87 7: 13 8–10: 0 | 8 | 78 | 2 | nd | 0.5–1.0 cm | nd
| EBRT (3D-CRT) Level 5, Disease group 2 | 101 | | nd | 100 | ≤10: 43 20: 41 ≥20: 17 | 2–6: 12 7: 71 8–10: 17 | 34 | 78 | 2 | nd | 0.5–1.0 cm | nd
Retrospective Cohort Study
Eade 2007 17398026 USA | EBRT (3D-CRT: <70 Gy) | 43 | 73 | nd | 100 | <10: 58 10–20: 28 >20: 14 | 2–6: 98 7: 2 8–10: 0 | 0 | 70 | nd | alpha cradle cast | 1.0 cm | nd | B com-5
Eade 2007 17398026 USA | EBRT (3D-CRT: 70–74.9 Gy) | 552 | 69 | | 95 | <10: 66 10–20: 23 >20: 11 | 2–6: 80 7: 18 8–10: 2 | 0 | 70–74.9 | nd | | | nd
Eade 2007 17398026 USA | EBRT (3D-CRT: 75–79.9 Gy) | 568 | 68 | | 96 | <10: 62 10–20: 27 >20: 11 | 2–6: 81 7: 15 8–10: 4 | 0 | 75–79.9 | nd | | | nd
Eade 2007 17398026 USA | EBRT (3D-CRT: ≥80 Gy) | 367 | 69 | | 96 | <10: 58 10–20: 34 >20: 8 | 2–6: 45 7: 51 8–10: 4 | 0 | ≤80 | nd | | | nd
Goldner 2009 19240995 Austria | EBRT 66 Gy (1994–1998) | 117 | 70 | nd | 85 | ≤10: 48 >10–20: 39 | ≤6: 93 | 44 | 66 | nd | Endorectal balloon | 1.5–2.0 cm | nd | B com-3
Goldner 2009 19240995 Austria | EBRT 70 Gy (1998–2003, not high risk) | 165 | 71 | | 96 | ≤10: 69 >10–20: 30 | ≤6: 80 | 68 | 70 | | nd | 0.5–1.0 cm | nd
Goldner 2009 19240995 Austria | EBRT 74 Gy (1998–2003, high risk only; 2003+, all pts) | 116 | 71 | | 74 | ≤10: 44 >10–20: 31 | ≤6: 62 | 81 | 74 | | nd | 0.5–1.0 cm | nd
Hanssen 2008 19031926 Norway | EBRT (Conformal technique) | 57 | 65.5 | nd | nd | nd | nd | nd | 70 | 2 | nd | nd | nd | C com-1
Hanssen 2008 19031926 Norway | EBRT (BeamCath® technique) | 23 | 66.2 | nd | nd | nd | nd | nd | 76 | 2 | nd | 1.0–1.5 cm | nd
Jani AB 2007 17241095 USA | EBRT (4,6 field or 3D conformal) | 373 | 67.6 | White: 51% African American: 43% Other: 6% | 82 | 9.5 | 2–6: 62 7: 28 8–10: 9 Not recorded: 1 | 53 | 70.0 | 1.8–20 | nd | 1.0 cm | AcQSim VoxelQ software | C com-2
Jani AB 2007 17241095 USA | EBRT (IMRT) | 108 | 69 | White: 42% African American: 54% Other: 4% | 99 | 7.6 | 2–6: 48 7: 45 8–10: 7 | 51 | 76.0 | | nd | 1.0 cm & 0.5 cm posteriorly | Corvus inverse planning system
Jani AB 2007 16983394 USA | EBRT (4,6 field or 3D conformal) | 355 | 67.7 | White: 50% African American: 43% Other: 6% | 82 | 9.5 | 2–6: 63 7: 28 8–10: 9 | 38 | 70.0 | 1.8–20 | nd | 1.0 cm | AcQSim VoxelQ software | C com-2
Jani AB 2007 16983394 USA | EBRT (IMRT) | 106 | 68.9 | White: 42% African American: 55% Other: 4% | 98 | 7.6 | 2–6: 49 7: 44 8–10: 7 | 51 | 76.0 | | nd | 1.0 cm & 0.5 cm posteriorly | Corvus inverse planning system
Kupelian 2008 17996382 USA | EBRT (<72 Gy) | 552 | 69 (overall for all 3 groups) | Black: 23 (overall) | 93 | >4 to ≤10: 42 >10 to ≤20: 27 >20: 22 | 2–6: 63 | 0 | 68.4 | 1.8–2.0 | nd | nd | nd | B com-6
Kupelian 2008 17996382 USA | EBRT (72–82 Gy) | 215 | | | 93 | >4 to ≤10: 63 >10 to ≤20: 23 >20: 7 | 2–6; 69 | 0 | 78 | | nd | nd | nd
Kupelian 2008 17996382 USA | EBRT (≥82 Gy) | 152 | | | 100 | >4 to ≤10: 74 >10 to ≤20: 17 >20: 1 | 2–6 80 | 0 | 70 (equiv 83 Gy) | 2.5 | nd | nd | nd
Wong 2009 19670452 And Vora 2007 17398023 USA | EBRT (3D-CRT) | 270 | nd | nd | 90 | ≤10: 71 10.1–20: 19 ≥20: 10 | ≤6: 65 | 17 | 68.4 | 1.8 to 2 | nd | 1.0–2.0 cm | none | B
Wong 2009 19670452 And Vora 2007 17398023 USA | EBRT (IMRT) | 314 | nd | nd | 96 | ≤10: 76 10.1–20: 17 ≥20: 7 | ≤6: 44 | 36 | 75.6 | nd | nd | 0.6–1.0 cm | nd
Wong 2009 19670452 And Vora 2007 17398023 USA | BT | 225 | nd | nd | 100 | ≤10: 86 10.1–20: 12 ≥20: 2 | ≤6: 77 | 32 | I-125: 144 Gy pd-103: 120 Gy | n/a | nd | n/a | nd
Wong 2009 19670452 And Vora 2007 17398023 USA | EBRT+BT | 44 | nd | nd | 98 | ≤10: 65 10.1–20: 30 ≤20: 5 | ≤6: 45 | 27 | EBRT: 45 Gy, followed by 110 Gy using I-125, or 90 Gy using Pd-103 seeds. | nd | nd | nd | nd
Zelefsky 2008 18280056 USA | EBRT (3-D CRT) | 2047 | 69 (overall) | nd | 83 | <10: 56 10–20: 26 >20: 18 | ≤6: 47 7: 36 ≥8: 17 | 52 | 64.8–75.6 | 1.8 | nd | 1.0 cm & 0.6 cm posteriorly | nd | B com-3
Zelefsky 2008 18280056 USA | EBRT (IMRT) | | | | | | | | 81 or 86.4 | 1.8 | nd | 1.0 cm & 0.6 cm posteriorly | nd
Zelefsky 2008 18313526 USA | EBRT (3-D CRT-70.2Gy) | 358 | 69 (overall) | nd | nd | nd | nd | 43 (overall) | 70.2 | 1.8 | nd | nd | nd | B com-2
Zelefsky 2008 18313526 USA | EBRT (3-D CRT-75.6 Gy) | 472 | | | nd | nd | nd | | 75.6 | 1.8 | nd | nd | nd
Zelefsky 2008 18313526 USA | EBRT (IMRT-81 Gy) | 741 | | | nd | nd | nd | | 81 | nd | nd | nd | nd

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table E2 Genitourinary toxicity: EBRT dose comparisons (qualitative)

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GU ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Prospective cohort studies
Late GU ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Michalski (2010) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Lin (2007) | No diff | C
Retrospective cohort studies
Acute GU ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N= 643) | Wong (2009) | No diff | B
Acute GU ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N= 643) | Jani (2007) | No diff | C
| Higher (N=741^B^) vs. lower dose (N=830^B^) | Zelefsky (2008)^A^ | High is worse | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Goldner (2009) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Wong (2009) | No diff | B
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Hanseen (2008) | No diff | C
Late GU ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Jani (2007) | No diff | C
Late GU ≥ Grade 3 | High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | High is worse | B

Better: statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

No difference: no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Worse: statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Bold words signify statistical significance P<0.05

A ≥ Grade 2 GU toxicity

B estimated; as high (81 Gy) was only worse for those with IMRT, unclear how many without IMRT received high dose

Table E3 Gastrointestinal toxicity: EBRT dose comparisons (qualitative)

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GI ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 195) vs. lower dose (N= 196) | Zietman (2005) | No diff | B
Prospective cohort studies
Late GI ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Michalski (2010) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 958) vs. lower dose (N= 400) | Lin (2007) | No diff | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N= 643) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | Higher dose (N= 422) vs. lower dose (N= 643) | Jani (2007) | No diff | C
| High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | No diff^a^
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Goldner (2009) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Hanseen (2008) | No diff | C
Late GI ≥ Grade 3 | Higher dose (N= 724) vs. lower dose (N= 799) | Jani (2007) | No diff | C
Late GI ≥ Grade 3 | High (N=741), medium (N=472), low (N=358) | Zelefsky (2008)^A^ | medium is worst | B

Better: statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

No difference: no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Worse: statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing EBRT higher dose with EBRT lower dose

Bold words signify statistical significance P<0.05

a ≥ Grade 2 GI toxicity

Figure E1 Freedom from biochemical failure: EBRT dose comparisons (5 years of follow-up)

$Kuban (2008) also provided 10-year follow-up data; *Eade (2007) also provided 8-year follow-up data; #Data presented here were from a subgroup of patients who did no received ADT; @ Data presented here were from low and intermediate risk groups; **Zietman recently published 10-year follow-up data for patients originally reported in Zietman 2005 (see Figure 6)

Figure E2 Freedom from biochemical failure: EBRT dose comparisons (>5 years of follow-up)

$Kuban (2008) also provided 5-year follow-up data; *Eade (2007) also provided 5-year follow-up data; **Zietman 2010 provided follow-up data for patients originally reported in Zietman 2005

Figure E3 Genitourinary and gastrointestinal toxicity: EBRT dose comparisons

## Standard vs. Hypofractionation EBRT Comparisons

(Tables E4–E6; Figure E4)

### Randomized controlled trials (RCTs)

(Table E4)

Four RCTs compared standard fractionation with hypofractionation.43, 44, 46, 73 The sample size ranged from 91 to 936. Two studies included only patients with T1 or T2 disease, 43, 44 two studies included up to 14&#x00025; of patients with T3 or higher stage disease.46, 73 One study included 44&#x00025; of patients who received some form of ADTs.46 The methodological quality of 3 studies were rated B and one was rated C. A common methodological deficiency in these studies was suboptimal reporting.

#### Biochemical control and survival

Three RCTs reported outcomes on biochemical control using a composite definition including clinical failure and PSA concentration.43, 44, 73 One trial found a significant decrease in the probability of biochemical or clinical progression at 5 years in the standard fractionation compared to the hypofractionation arm (53&#x00025; vs. 60&#x00025;, yielding a risk difference of &#x02212;7&#x00025; (95&#x00025; CI &#x02212;12.6&#x00025; to &#x02212;1.4&#x00025;)).43 Overall survival at 5 years was estimated as 85&#x00025; and 88&#x00025; in the standard fractionation and the hypofractionation arms, respectively (HR 0.85; 95&#x00025;CI, 0.63 to 1.15). One trial did not find a significant difference in the actuarial 5-year biochemical relapse free (with or without clinical relapse) survival between conventional EBRT (55.5&#x00025;) and hypofractionated EBRT (57.4&#x00025;).44 One trial reported three cases of biochemical relapse (out of 43) in the standard arm and two cases in the hypofractionation arm (out of 46) during a 12-month follow-up. 73 No statistical comparison was provided.

#### Genitourinary toxicity

(Table E5, Figure E4)

Two RCTs provided data on grade 3 or grade 4 genitourinary toxicity.43, 46 One trial reported that the acute genitourinary toxicity was slightly lower in the standard fractionation arm (4.9&#x00025;) compared with the hypofractionation arm (8.6&#x00025;) (&#x00025; difference &#x02212;3.7&#x00025;; 95&#x00025; CI, &#x02212;7.0&#x00025; to &#x02212;0.5&#x00025;); however, late toxicity was similarly low in both arms (1.9&#x00025;).43 One trial reported that no patients in either arm experienced grade 3 or grade 4 genitourinary toxicity.46

#### Gastrointestinal toxicity

(Table E6, Figure E4)

The same RCTs provided data on grade 3 or grade 4 gastrointestinal toxicity. One trial reported that the acute gastrointestinal toxicity was non-significantly lower in the standard fractionation arm (2.6&#x00025;) compared with the hypofractionation arm (4.1&#x00025;) (&#x00025;difference &#x02212;1.5&#x00025;; 95&#x00025; CI, &#x02212;4.0&#x00025; to 0.8&#x00025;); however, late toxicity was similarly low in both arms (1.3&#x00025;).43 One trial reported that no patients in either arm experienced grade 3 or grade 4 gastrointestinal toxicity.46

### Prospective studies

No prospective cohorts that compared standard fractionation with hypofractionation met our inclusion criteria.

### Retrospective studies

(Table E4–E6, Figure E4)

Two retrospective analyses of the same cohort (one using the accrued sample between 2002 and 2004^74^ and the other using the accrued sample between 2002 and 2006^45^) reported the acute and late genitourinary or gastrointestinal toxicities. The first analysis had 130 patients and reported the acute genitourinary and gastrointestinal toxicity among 3 different fractionation groups.74 The acute genitourinary toxicity grade &#x02265;3 was 2.7&#x00025; in 2 Gy/fraction group, 0&#x00025; in 3 Gy/fraction group, and 5.9&#x00025; in 3.15Gy/fraction group. The acute gastrointestinal toxicity grade &#x02265;3 were reported to be 2.7&#x00025; in 2 Gy/fraction group, 0&#x00025; in both 3Gy/fraction and 3.15Gy/fraction groups. The methodological quality of this analysis was rated C because there was no statistical adjustment for potential confounders.

The second analysis had 219 patients.45 This study reported the late genitourinary or gastrointestinal toxicities. Comparing standard fractionation (2 Gy/fraction) with hypofractionation (either 3 Gy/fraction or 3.15 Gy/fraction), late genitourinary toxicity grade &#x02265;3 was 0.8&#x00025; versus 2.2&#x00025; (P = NS); for late gastrointestinal toxicity grade &#x02265;3, it was 1.5&#x00025; versus 1.1&#x00025; (P = NS). There was no statistical difference in the late toxicities between the 3 Gy/fraction and the 3.15 Gy/fraction groups (data not provided in the analysis). The methodological quality of this analysis was rated B.

Table E4 Characteristics of studies that compared different EBRT fraction sizes

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Comments
RCT
Lukka 2005 16135479 Canada | EBRT (Long arm: 66 Gy in 33 fractions) | 470 | 70.3 | nd | 100 | 10.4(0.4–40) | 2–6: 59 7: 33 8–10: 8 | 0 | 66 | 2 | nd | 1.5-cm & 1.0 cm posteriorly | nd | B com-8
Lukka 2005 16135479 Canada | EBRT (Short arm: 52.5 Gy in 20 fractions) | 466 | 70.0 | nd | 100 | 10.6(0.3–39) | 2–6: 60 7: 29 8–10: 11 | 0 | 52.5 | 2.6 | nd | 1.5 cm & 1.0 cm posteriorly | nd
Norkus 2009 19605967 Lithuania | EBRT (Standard fractionation) | 44 | 65 | nd | 95 | ≤10: 100 | ≤6: 100 | 0 | 74 | 2 | nd | 0.8–1.0 cm | nd | C com-4, 8
Norkus 2009 19605967 Lithuania | EBRT (Hypo fractionation) | 47 | 63 | | 98 | ≤10: 100 | ≤6: 96 | 0 | 57 | 13 fractions of 3 Gy; 4 fractions of 4.5 Gy | nd | 0.8–1.0 cm | nd
Pollack 2006 16242256 USA | Conventional fractionation IMRT | 50 | nd | nd | 86 | <10: 60 10–20: 30 >20: 10 | 5–6: 30 7: 48 8–10: 22 | 44 | 76 | 2 | nd | 0.8 cm & 0.5 cm posteriorly | Corvus treatment planning system | B com-2
Pollack 2006 16242256 USA | Hypofractionation IMRT | 50 | nd | nd | 86 | <10: 52 10–20: 32 >20: 16 | 5–6: 48 7: 36 8–10: 16 | 44 | 70.2 | 2.7 | nd | 0.7 cm & 0.3 cm posteriorly
Yeoh 2006 16965866 Australia | EBRT (Conventional 2D or 3D RT-64 Gy) | 109 | 69 overall | nd | 100 | <10: 49.5 10–20: 41 >20: 9 | 2–6: 81 7: 15 8–10: 4 | 0 | 64 | 2 | nd | 1.5 cm 95% isodose margin | Pinnacle | B com-7
Yeoh 2006 16965866 Australia | EBRT (Hypofractionated 2D or 3D RT-55 Gy) | 108 | | nd | 100 | <10: 43.5 10–20: 38 >20: 18.5 | 2–6: 79 7: 14 8–10: 9 | 0 | 55 | 2.75 | nd | 1.5 cm 95% isodose margin | Pinnacle
Retrospective Cohort Study
Leborgne F 2008 18375075 Uruguay | EBRT (Standard fractionation) | 74 | 68 | nd | 95 (overall) | | | 36 | 78 | 2 | | 1.1 cm & 0.5 cm posteriorly | XiO computerized treatment planning system | C com-1
Leborgne F 2008 18375075 Uruguay | EBRT (Hypofractionation-3Gy/fraction) | 22 | 70 | nd | | | | 19 | 60 | 3 | | No PTV2 rectal shielding
Leborgne F 2008 18375075 Uruguay | EBRT (Hypofractionation-3.15Gy/fraction) | 34 | 69 | nd | | | | 29 | 63 | 3.15 | | No PTV2 rectal shielding
Leborgne F 2009 19395194 Uruguay | EBRT (Standard fractionation) | 130 | 68 | nd | 100 | Median 8ng/ml | Median 6 | 31 | 63 | 3.15 | | 1.1 cm & 0.5 cm posteriorly | XiO computerized treatment planning system | B
Leborgne F 2009 19395194 Uruguay | EBRT (Hypo fractionation) | 89 | 70 | | 97 | Median 10ng/ml | Median 6 | 35 | 78 | 2 | | No PTV2 rectal shielding

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table E5 Genitourinary toxicity: EBRT fraction size comparisons (qualitative)

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GU ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | Long arm is better | B
Acute GU ≥ Grade 3 | Conventional fractionation (N=50) vs. hypofractionation IMRT (N=50) | Pollack (2006) | No diff | B
Late GU ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Retrospective cohort studies
Acute GU ≥ Grade 3 | Standard fractionation (N=74) vs. hypofractionation-3Gy/fraction (N=22) vs. hypofractionation-3.15Gy/fraction EBRT (N=34) | Leborgne (2008)) | No diff | C
Late GU ≥ Grade 3 | Standard fractionation (N=130) vs. hypofractionation EBRT (N=89) | Leborgne (2009) | No diff | B

Better: statistically significant risk difference in increasing acute/late GI toxicity, comparing EBRT fraction sizes

No difference: no statistically significant risk difference in acute/late GI toxicity, comparing EBRT fraction sizes

Worse: statistically significant risk difference in decreasing acute/late GI toxicity, comparing EBRT fraction sizes

Bold words signify statistical significance P<0.05

Table E6 Gastrointestinal toxicity: EBRT fraction size comparisons (qualitative)

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
RCTs
Acute GI ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Acute GI ≥ Grade 3 | Conventional fractionation (N=50) vs. hypofractionation IMRT (N=50) | Pollack (2006) | No diff | B
Late GI ≥ Grade 3 | EBRT (Long arm: 66 Gy in 33 fractions) (N=470) vs. EBRT (Short arm: 52.5 Gy in 20 fractions) (N=466) | Lukka (2005) | No diff | B
Retrospective cohort studies
Acute GI ≥ Grade 3 | Standard fractionation (N=74) vs. hypofractionation-3Gy/fraction (N=22) vs. hypofractionation-3.15Gy/fraction EBRT (N=34) | Leborgne (2008) | No diff | CB
Late GI ≥ Grade 3 | Standard fractionation (N=130) vs. hypofractionation EBRT (N=89) | Leborgne (2009) | No diff | B

Better: statistically significant risk difference in increasing acute/late GI toxicity, comparing EBRT fraction sizes

No difference: no statistically significant risk difference in acute/late GI toxicity, comparing EBRT fraction sizes

Worse: statistically significant risk difference in decreasing acute/late GI toxicity, comparing EBRT fraction sizes

Bold words signify statistical significance P<0.05

Figure E4 Genitourinary and gastrointestinal toxicity: EBRT fraction size comparisons

## Other Intra-EBRT Comparisons

(Table E7)

### Randomized controlled trials (RCTs)

(Table E7)

One RCT compared EBRT using endorectal balloon for prostate immobilization with EBRT not using endorectal balloon.47 All 48 patients received some form of ADTs. No data on T staging were reported. There were no differences in the acute genitourinary or gastrointestinal toxicity ≥ grade 3 in the two groups (no events in either group). In terms of chronic genitourinary toxicity ≥ grade 3 comparing EBRT with endorectal balloon versus without endorectal balloon, there were no events reported in either group. In terms of chronic gastrointestinal toxicity ≥ grade 3 comparing EBRT with endorectal balloon versus without endorectal balloon, it was 0% versus 4% (no P value reported). The methodological quality of this study was rated B because of suboptimal reporting.

### Prospective studies

(Table E7)

One prospective cohort compared patients who received conformal radiotherapy to the prostate only (CRT-PO) with patients who received whole pelvis and prostate boost radiotherapy (WP+PB).48 Fifty one patients received CRT-PO and 46 received WP+PB. The CRT-PO group tended to be slightly older men (mean 70 years) with stage T1 or T2 disease with lower PSA values (median 9 ng/mL), lower Gleason scores (78% ≤ 7) who largely did not receive ADTs. The WP+PB group tended to have somewhat younger men (mean 67 years), with stage T2 or T3 disease, higher PSA values (median 16.5 ng/mL), higher Gleason scores (59% ≤ 7) and most received some form of ADTs (91%). The study reported radiation induced fatigue based on fatigue pictogram, questionnaire, and fatigue scale (range 0–44, 0 = best and 44 = worst). A significant number of patients reported some level of fatigue at baseline. The fatigue scale showed that those receiving WP+PB reported higher scores compared to CRT-PO (baseline: CRT-PO 3.3 vs. WP+PB 4.6; week 6: CRT-PO 4.2 vs. WP+PB 6.2). The methodological quality of this study was rated C. There was no statistical adjustment for potential confounders.

### Retrospective studies

(Table E7)

One retrospective cohort study evaluated the effect of different 3D-CRT nodal target coverage on biochemical failure-free survival (bFFS).49 Of the 669 patients evaluated, 384 underwent mini pelvis (MP) field treatment (excluding common iliac nodes) and 285 underwent whole pelvis (WP) field treatment (including common iliac nodes). Some form of ADTs were used in 45% of the patients and 11% of the patients had stage T3 disease. This study observed that the pretreatment PSA level, Gleason score, T stage, and the use of ADT were predictors of treatment response. An increase in bFFS in the MP field arm compared to the WP field arm was observed on univariate analysis, but not on multivariate analysis when corrected for factors including age at diagnosis, pretreatment PSA level, Gleason score, T stage, ADT, total radiation dose, and year of radiation treatment (HR 0.94, 95% CI 0.66 to 1.33, P = 0.71). The methodological quality of this study was rated B.

One retrospective cohort study compared the effects of 3D-CRT versus 2D-CRT on anorectal function in 67 patients; the chronic grade ≥3 rectal toxicity at 2 years was 10% versus 8%, respectively.50 The methodological quality of this study was rated C. There was no statistical adjustment for potential confounders.

Table E7 Characteristics of studies that compared other EBRT technique comparisons

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
RCT
Van Lin 2007 17161552 Netherlands | 3D CRT with ERB | 24 | nd | nd | nd | nd | nd | 100 | 67.5 | 2.25 | Endorectal balloon | 0.9cm | Pinnacle | B com-8
Van Lin 2007 17161552 Netherlands | 3D CRT no ERB | 24 | nd | nd | nd | nd | nd | 100 | 67.5 | 2.25 | | 0.9cm | Pinnacle
Prospective Cohort Study
Danjoux 2007 17333296 Canada | Conformal radiotherapy | 51 | 70.3 | nd | 98 | 9 | 5–6: 31 7: 47 8–10: 22 | 24 | 70–76 | 2 | four-field conformal technique with an 18 MV photon beam | nd | nd | B
Danjoux 2007 17333296 Canada | Whole pelvis and prostate boost radiotherapy | 46 | 67.4 | nd | 61 | 16.5 | 5–6: 8 7: 48 8–10: 43 | 91 | whole pelvis: 45 Gy in 25 fractions prostate boost: 26 Gy in 13 fractions | 1.8–2.0 | four-field conformal technique with an 18 MV photon beam | nd | nd
Retrospective Cohort Study
Soto DE 2008 18308110 USA | EBRT (Whole pelvis 3D CRT) | 384 | 70.3 | nd | 86 | 25.1 | 2–6: 31 7: 42 8–10: 27 | 37 | 71 | | nd | 1–2 cm | nd | B
Soto DE 2008 18308110 USA | EBRT (Mini Pelvis 3D CRT) | 285 | 69.0 | nd | 92 | 16.5 | 2–6: 32 7: 43 8–10: 25 | 52 | 75 | | nd | 1–2 cm | nd
Yeoh 2009 18571336 Australia | EBRT (2D RT) | 38 | 68 | nd | nd | nd | nd | nd | 55 / 64 | 2.75/2.0 | nd | 1.5 cm isodose margin | Pinnacle | C Com-1
Yeoh 2009 18571336 Australia | EBRT (3D RT) | 29 | 71 | nd | nd | nd | nd | nd | 55 / 64 | 2.75/2.0 | nd | 1.5 cm isodose margin | Pinnacle

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported