# Detailed results for the comparisons in combination therapies

## Combination Therapies: LDRBT plus EBRT in different doses

(Tables D1–D5)

### Randomized controlled trials (RCTs)

(Tables D1)

One RCT, enrolling a total of 159 patients, compared LDRBT plus 20 Gy of EBRT (N = 83) against LDRBT plus 44 Gy of EBRT (N = 76), with 23% and 41% of patients receiving some form of ADTs, respectively.27 This study enrolled only patients with T1c-T2a cancer, and the methodological quality of the study was rated B.

#### Biochemical failure

There was no significant difference in the 3-year actuarial freedom from biochemical failure rate between the two arms, with respective failure rates of 83% and 88% (P = 0.64).

### Prospective studies

There were no prospective studies comparing LDRBT versus EBRT in different doses for the treatment of localized prostate cancer that met our inclusion criteria.

### Retrospective studies

There were no retrospective studies comparing LDRBT versus EBRT in different doses for the treatment of localized prostate cancer that met our inclusion criteria.

## Combination Therapies: EBRT vs. EBRT plus HDRBT

(Tables D1–D5, Figure D1)

### Randomized controlled trials (RCTs)

(Table D1)

One RCT, enrolling a total of 104 patients, compared EBRT (N = 53) against EBRT plus HDRBT (N = 51).28 No patients received ADTs, 40% of patients in this study had T3-T4 cancer. The methodological quality of this study was rated B.

#### Biochemical failure

There was no significant difference in biochemical failure rates between the two arms, after a mean follow-up period of 8.2 years. The failure rate of the EBRT arm was 83%, compared to 88% for the EBRT plus HDRBT arm (P = 0.37).

### Prospective studies

(Table D2)

One prospective study, enrolling a total of 97 patients, compared EBRT (N = 57) against EBRT plus HDRBT (N = 40).65 Up to 11% of patients had T3 or T4 cancer and 36.8% of patients in the EBRT arm and 42.5% of patients in the EBRT plus HDRBT arm received some form of ADTs. This study was rated C because of unclear study description and suboptimal reporting of results.

#### Genitourinary toxicity

(Table D4, Figure D1)

No patients in the EBRT plus HDRBT arm experienced grade 3 or grade 4 genitourinary toxicity, while 1.7% of patients in the EBRT arm did. No P values were reported for this comparison.

#### Gastrointestinal toxicity

(Table D5, Figure D1)

No patients in the EBRT plus HDRBT arm experienced grade 3 or grade 4 gastrointestinal toxicity, while 8.8% of patients in the EBRT arm did. No P values were reported by the study investigators, our own calculation showed a P value of 0.15.

### Retrospective studies

(Table D3)

One study enrolled a total of 111 patients, with 10% of patients having T3 or T4 cancer in the EBRT arm (N = 88), compared to 17% in the EBRT plus HDRBT arm (N = 23).30 Data on the proportion of patients receiving ADTs was not reported. The methodological quality of this study was rated B.

#### Quality of life

No significant difference was found between the EBRT and EBRT plus HDRBT arms with respect to health-related quality of life after one year, utilizing a modified Functional Assessment of Cancer Therapy-Prostate (FACT-P) survey instrument. A higher total score on the FACT-P scale indicates a better overall quality of life. Patients in the EBRT arm had a mean score of 97.64, while patients in the EBRT plus HDRBT arm had a mean score of 95.04 (P = 0.668).

## Combination Therapies: EBRT plus LDRBT vs. EBRT plus HDRBT

(Tables D2; D4–D5, Figure D1)

### Randomized controlled trials (RCTs)

There were no RCTs comparing EBRT plus LDRBT versus EBRT plus HDRBT for the treatment of localized prostate cancer that met our inclusion criteria.

### Prospective studies

(Tables D2, D6)

One study enrolled a total of 110 patients, with 49 patients in the EBRT plus HDRBT group and 61 in the EBRT plus LDRBT group.29 There were no data on the proportion of patients with stage T3/T4 cancer or the proportion who received some form of ADTs. The methodological quality of this study was rated B. It was unclear how many patients were eligible for the study but not included in the analysis.

#### Genitourinary toxicity

(Table D4, Figure D1)

No significant difference was found in the Prostate Symptom Self Report (PSSR) Urinary Score after one year. The PSSR has a range from 0-100, in which higher scores indicate worse symptoms. It measures the frequency, severity, bothersomeness, and quality of urinary, bowel, and sexual symptoms experienced during the past month. Patients in the EBRT plus LDRBT group had a mean increase of 8.98 from baseline, while those in the EBRT plus HDRBT group had a mean increase of 2.79 from baseline (our calculation showed a P value of 0.10).

#### Gastrointestinal toxicity

(Table D5, Figure D1)

No significant difference was found in the PSSR Bowel Score after one year. Patients in the EBRT plus LDRBT group had a mean increase of 4.73 from baseline, while those in the EBRT plus HDRBT group had a mean increase of 5.25 from baseline (P = 0.85).

#### Sexual dysfunction

No significant difference was found in PSSR Sexual Score after one year. Patients in the EBRT plus LDRBT group had a mean increase of 10.72 from baseline, while those in the EBRT plus HDRBT group had a mean increase of 9.61 from baseline (P = 0.77).

### Retrospective studies

There were no retrospective studies comparing EBRT plus LDRBT versus EBRT plus HDRBT in different doses for the treatment of localized prostate cancer that met our inclusion criteria.

## Combination Therapies: LDRBT vs. LDRBT plus EBRT

(Tables D3–D6, Figure D1)

### Randomized controlled trials (RCTs)

There were no RCTs comparing LDRBT versus LDRBT plus EBRT for the treatment of localized prostate cancer that met our inclusion criteria.

### Prospective studies

There were no prospective studies comparing LDRBT versus LDRBT plus EBRT for the treatment of localized prostate cancer that met our inclusion criteria.

### Retrospective studies

(Table D3)

There were two retrospective studies comparing LDRBT versus LDRBT plus EBRT for the treatment of localized prostate cancer that met our inclusion criteria. One enrolled a total of 30 patients, with 15 in each group and none of whom had T3/T4 cancer, with no data on ADT treatment66 The methodological quality of this study was rated C. This study had different selection criteria for the different comparison arms and there was no adjustment for potential confounders.

Another study enrolled a total of 343 patients.67 In the LDRBT arm [N = 216], no patients had T3/T4 cancer, and 1% had been treated with ADT. In the LDRBT plus EBRT arm [N = 127], 2% of patients had T3/T4 cancer, and 34% had been treated with ADT. The methodological quality of this study was rated C. Baseline characteristics between groups were not entirely comparable; there was no adjustment for potential confounders.

#### Genitourinary toxicity

(Table D4, D6, Figure D1)

First study reported no significant difference in the International Prostate Symptom Score (IPSS) score after 4 months between the two arms.66 In the IPSS, a higher score indicate increased dysfunction. Patients in the LDRBT arm had a mean score of 9.5, while those in the LDRBT plus EBRT arm had a mean score of 12.0 (P = 0.39).

In the second study, 6% of the LDRBT group had acute urinary toxicity of grade 3 or grade 4 and none had late urinary toxicity of grade 3 or grade 4, while 2% of the LDRBT plus EBRT group had acute urinary toxicity and 1% had late urinary toxicity67 P-values were not provided for the comparison.

#### Gastrointestinal toxicity

(Table D5, Figure D1)

One study reported no patients as having either acute rectal toxicity of grade 3 or grade 4 or late rectal toxicity of grade 3 or grade 4.^67^

## Combination Therapies: EBRT plus BT vs. No Radiotherapy, EBRT, or BT

(Tables D3–D4)

In this comparison, BT refers to brachytherapy in general, i.e., studies that did not specify the type of brachytherapy.

### Randomized controlled trials (RCTs)

There were no RCTs examining this particular comparison that met our inclusion criteria.

### Prospective studies

There were no prospective studies examining this particular comparison that met our inclusion criteria.

### Retrospective studies

(Table D3)

There were two retrospective studies comparing EBRT plus BT versus no treatment or no initial treatment for the treatment of localized prostate cancer that met our inclusion criteria. Both studies analyzed SEER data. One study evaluated 231 patients in the EBRT plus BT group and 378 in the no radiotherapy group.18 Two percent of patients had T3/T4 cancer, and no data was reported on the proportion of patients who had ADTs. The methodological quality of this study was rated as B.

Another study evaluated 9,096 patients in the EBRT plus BT group and 40,733 in the no radiotherapy or surgery group, with 20.5% of patients having T3/T4 cancer in the EBRT + BT arm, and 21.9% in the no radiotherapy or surgery arm.14 There were no data on the proportion of patients who had ADTs. The methodological quality of this study was rated B.

#### Genitourinary toxicity

(Table D4)

One study reported a significantly higher incidence of urethral strictures in the BT + EBRT arm than in the EBRT arm at a median follow-up of 2.7 years. 5.2% of patients in the BT + EBRT arm had urethral strictures, compared to 1.7% in the EBRT arm.18

#### Second primary cancer

(Table D4)

One study reported on the incidence of second primary cancers in patients treated with EBRT and in patients treated with combination EBRT plus BT.14 The study did not directly compare the two groups. Our own calculation showed the incidence of second primary cancers to be significantly greater in the EBRT group compared to the EBRT plus BT group (10.3% vs. 5.7%; OR 1.9, 95%CI, 1.7 to 2.1). Our own calculation also showed the incidence of late second primary cancers to be significantly greater in the EBRT group compared to the EBRT plus BT group (4.2% vs. 1.4%; OR 3.0, 95%CI, 2.5 to 3.6).

## Combination Therapies: EBRT (3D-CRT) plus LDRBT vs. LDRBT, or EBRT (3D-CRT), or EBRT (IMRT)

(Tables D3–D5, Figure D1)

In this comparison, BT refers to brachytherapy in general, i.e., studies that did not specify the type of brachytherapy.

### Randomized controlled trials (RCTs)

There were no RCTs examining this particular comparison that met our inclusion criteria.

### Prospective studies

There were no prospective studies examining this particular comparison that met our inclusion criteria.

### Retrospective studies

(Table D3)

There was one retrospective study comparing EBRT (3D-CRT) plus LDRBT [N= 44] versus LDRBT [N = 225], EBRT (3D-CRT) [N = 270], or EBRT (IMRT) [N = 314] for the treatment of localized prostate cancer that met our inclusion criteria.22 Ninety percent of patients had stage T1 or T2 disease in the EBRT arm, compared to 98% in the EBRT plus HDRBT arm. Data on the proportion of patients who had ADTs was not reported. The methodological quality of this study was rated B.

#### Biochemical control

As the study did not directly compare LDRBT plus EBRT against EBRT or LDRBT, our own analysis showed no significant difference in 5-year biochemical control in these two comparisons (P = 0.142 and P = 0.8, respectively). Patients in the LDRBT plus EBRT arm had a control rate of 94%, while those in the EBRT arm had a rate of 87% and those in the LDRBT arm had a rate of 94%.

#### Genitourinary toxicity

(Table D4, Figure D1)

Our analysis showed no significant difference in acute grade 3 genitourinary toxicity when comparing LDRBT plus EBRT against EBRT (P = NS), nor was there a significant difference found when comparing LDRBT plus EBRT against LDRBT (P = NS). There was a significant difference found in late grade 3 genitourinary toxicity when comparing LDRBT plus EBRT against EBRT (P < 0.05), but there was not a significant difference found when comparing LDRBT plus EBRT against LDRBT (P = NS).

#### Gastrointestinal toxicity

(Table D5, Figure D1)

Our analysis showed no significant difference in either acute or late grade 3 gastrointestinal toxicity when comparing LDRBT plus EBRT against EBRT or when comparing LDRBT plus EBRT against LDRBT (P = NS).

Table D1 Characteristics of randomized controlled trials that compared combinations of radiotherapies with EBRT or LDRBT

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Sathya 2005 15718316 Canada | EBRT | 53 | 66 | nd | 60% | 20.2 | 2–6: 34% 7: 53% 8–10: 13% | 0% | 66 Gy in 33 fractions | 2 Gy/fraction | nd | nd | nd | B
Sathya 2005 15718316 Canada | HDRBT + EBRT | 51 | 65 | nd | 61% | 19.0 | 2–6: 37% 7: 45% 8–10: 18% | 0% | IM: 35 Gy EBRT: 40 Gy in 20 fractions | 2 Gy/fraction; 35 Gy over 48 hours | nd | 2cm | nd
Wallner 2005 16086912 USA | LDRBT (125 Gy) + EBRT (20 Gy) | 83 | 67 | nd | 100% | 7 | 2–6: 10.8% 7: 78.3% 8–10: 7.2% | 23% | 125 Gy LDRBT, 20 Gy EBRT | nd | nd | 2 cm margin, 1.0 cm posteriorly | nd | B
Wallner 2005 16086912 USA | LDRBT (125 Gy) + EBRT (44 Gy) | 76 | 67 | nd | 100% | 6.7 | 2–6: 15.8% 7: 75% 8–10: 9.2% | 41% | 125 Gy LDRBT, 44 Gy EBRT | nd | nd | nd | nd

Table D2 Characteristics of prospective cohort studies that compared combinations of radiotherapies with EBRT or LDRBT

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Lev 2009 18719947 US | EBRT (IMRT) + HDRBT | 49 | 68.4 | White 89.8, black 4.1, Hispanic 4.1, Asian 2.0 | nd | nd | nd | nd | nd | nd | nd | nd | nd | B com-2 com-6
Lev 2009 18719947 US | EBRT (IMRT) + LDRBT | 61 | 67.2 | White 82, black 11.7, Hispanic 3.3, asian 3.3 | nd | nd | nd | nd | nd | nd | nd | nd | nd
Soumarova 2007 17455870 Czech Republic | EBRT (3D CRT) | 57 | 69.9 | nd | 80.7 | ≤10: 47.4% 10–20: 28.1% >20: 24.5% | <4: 22.8% 4–6: 54.8% ≥7: 10.5% Unknown: 12.3% | 36.8% | Different dosages in different phrases. See table 2. | nd | nd | ? | nd | C com-2
Soumarova 2007 17455870 Czech Republic | EBRT (3D CRT) + HDRBT | 40 | 68.7 | nd | ≤10: 35% 10–20: 32.5% >20: 32.5% | <4: 25% 4–6: 65% ≥7: 10% | 42.5% | 3D CRT: 45Gy in 25 fractions if low risk; 50.4 Gy in 28 fractions if intermediate or high risk BT: 2×8 Gy (see table 1.) | nd | nd | 0.3cm (average) | nd

Table D3 Characteristics of retrospective cohort studies that compared combinations of radiotherapies with EBRT or LDRBT

Author Year [UI] Country | Intervention(s) or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Abdel-Wahab M 2008 18374503 US | EBRT | 48400 | 70.5(6.9) | nd | 79.9% | nd | nd | nd | nd | nd | nd | nd | nd | B
Abdel-Wahab M 2008 18374503 US | BT | 10223 | 66.7(7.7) | nd | 94.5% | nd | nd | nd | nd | nd | nd | nd | nd
Abdel-Wahab M 2008 18374503 US | EBRT + BT | 9096 | 66.7(7.8) | nd | 79.4% | nd | nd | nd | nd | nd | nd | nd | nd
Abdel-Wahab M 2008 18374503 US | No RT | 40733 | 73.1(9.0) | nd | 78.1% | nd | nd | nd | nd | nd | nd | nd | nd
Elliot 2007 17570425 US | BT, BT+EBRT, EBRT, WW | 6597 | >60yr: 1655 (25%) 60–69 yr: 2607 (40%) 70 yr or older: 2334 (35%) | ≤4: 952 (14%) 4.1–10: 4116 (62%) 10.1–20: 1029 (16%) >20: 499 (8%) | 98% | ≤4: 952 (14%) 4.1–10: 4116 (62%) 10.1–20: 1029 (16%) >20: 499 (8%) | 2–6: 4304 (65%) 7: 1723 (26%) 8–10: 569 (9%) | nd | nd | nd | nd | nd | nd | B com-2
Joseph 2008 18627617 Canada | EBRT | 88 | 69 (46–84) | nd | 90% | 8.7 median (1.7–161.8) | 55 scored 2–6 21 scored 7 12 scored 8–10 | nd | 66–70 | 2 | nd | 1–2 cm | nd | B
Joseph 2008 18627617 Canada | EBRT+HDRBT | 23 | 69 (50–78) | nd | 83% | 8.9 median (0.8–51.9) | 14 scored 2–6 7 scored 7 2 scored 8–10 | nd | 16.5 | 3 fractions | nd | 0.2–0.3 cm | nd
Song 2008 18714275 US | EBRT (IMRT) + LDRBT | 15 | 63.0(7.1) | nd | 100% | 7.4 | 6.9 | nd | 50.4 (95 for brachytherapy component) | 1.8 | Customized Thermoplastic mold | 1 cm 0.6-cm posteriorly. | MSKCC in house treatment planning system, most plans consisted of 5 coplanar beams at 225 degrees, 285 degrees, 0 degrees, 75 degrees, and 135 degrees. | C com-2
Song 2008 18714275 US | LDRBT | 15 | 65.7(7.6) | nd | 100% | 6.0 | 6.1 | nd | 144 | nd | nd | 0.5 cm, 0 cm posteriorly | MSKCC in house brachytherapy planning system
Wong 2009 19670452 USA | EBRT (3D-CRT) | 270 | nd | nd | 90 | ≤10: 71%, 10.1–20: 19%, ≥20: 10% | 65% ≤6 | 161 (28%) patients who received 3D-CRT or IMRT Median ADT duration = 9 mo (range, 1–72 mo), depending on the risk category | 45 Gy to the prostate and seminal vesicles, while the prostate was boosted to a median dose of 68.4 (range, 66–77 Gy) | 1.8 to 2 | nd | Customized blocking with a 1 – 2 cm margin from planning target volume to block edge | None | B
Wong 2009 19670452 USA | EBRT (IMRT) | 314 | nd | nd | 96 | ≤10: 76%, 10.1–20: 17%, ≥20: 7% | 44% ≤6 | 161 (28%) patients who received 3D-CRT or IMRT Median ADT duration = 9 mo (range, 1–72 mo), depending on the risk category | Median dose of 75.6 (range, 75.6–77.4 Gy) to prostate gland; 50.4 Gy to seminal vesicles | nd | nd | 0.6 – 1 cm | nd
Wong 2009 19670452 USA | LDRBT | 225 | nd | nd | 100 | ≤10: 86%, 10.1–20: 12%, ≥20: 2% | 77% ≤6 | 72 (32%) received short-term ADT median duration = 3 mo (range, 2–14 mo) | Minimal peripheral dose was 144 Gy for I-125 and 120 Gy for pd-103 | n/a | nd | n/a | nd
Wong 2009 19670452 USA | EBRT (3D-CRT)+LDRBT | 44 | nd | nd | 98 | ≤10: 65%, 10.1–20: 30%, ≥20: 5% | 45% ≤6 | 12 (27%) received short-term ADT. Duration was not reported. | 45 gy of EBRT to the prostate and seminal vesicles using 3D-CRT, followed by a BRT boost of 110 Gy using I-125, or 90 Gy using Pd-103 seeds. | nd | nd | nd | nd
Zelevsky 2008 18299108 US | LDRBT + EBRT (IMRT) | 127 | <65: 58 ≥65: 69 | nd | 98% | <10: 106 10–20: 20 >20: 1 | <=6 – 53 7 – 68 >= − 6 | 34% | 110 Gy (I-125 dose) + 50.4 Gy (IMRT) | 1.8 Gy fractions (IMRT) | nd | 1 cm around CTV(prostate and seminal vesicles) 0.3 cm margin posteriorly | Genetic optimization | C com-1 com-6
Zelevsky 2008 18299108 US | LDRBT | 216 | <65: 88 ≥65: 128 | nd | 100% | <10: 207 10–20: 9 >20: 0 | <=6 – 206 7 – 10 >= − 0 | 1% | 145 Gy | nd | nd | | nd

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table D4 Genitourinary toxicity: combinations of radiotherapies vs. EBRT or LDRBT (qualitative)

Outcome | Interventions or comparisons (total sample size) | Findings | | Quality
Prospective cohort studies
Disease-specific QoL: urinary scores | HDRBT+EBRT (N=49) vs. LDRBT+EBRT (N=61) | Lev (2009) | Better | B
Acute GU ≥ Grade 3 | HDRBT+EBRT (N=40) vs. EBRT (N=57) | Soumarova (2007) | No diff | C
Retrospective cohort studies
Disease-specific QoL: urinary scores | LDRBT+EBRT (N=15) vs. LDRBT (N=15) | Song (2008) | Worse | C
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Acute GU ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Late GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | Worse | B
Late GU ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Late GU ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Urethral strictures | BT+EBRT (N=231) vs. EBRT (N=645) | Elliott (2007) | Worse | B

QoL, quality of life; diff, difference

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing first treatment listed with second treatment listed

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

Bold words signify statistical significance P<0.05

* The same LDRBT+EBRT group was compared to EBRT (IMRT) or LDRBT group

Table D5 Gastrointestinal toxicity: combinations of radiotherapies vs. EBRT or LDRBT (qualitative)

Outcome | Interventions or comparisons (total sample size) | Findings | | Quality
Prospective cohort studies
Disease-specific QoL: bowel scores | HDRBT+EBRT (N=49) vs. LDRBT+EBRT (N=61) | Lev (2009) | No diff | B
Acute GI ≥ Grade 3 | HDRBT+EBRT (N=40) vs. EBRT (N=57) | Soumarova (2007) | Better | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Acute GI ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C
Late GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. EBRT (N=314) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | LDRBT+EBRT (N=44)^*^ vs. LDRBT (N=215) | Wong (2009) | No diff
Late GI ≥ Grade 3 | LDRBT+EBRT (N=127) vs. LDRBT (N=216) | Zelefsky (2008) | No diff | C

QoL, quality of life; diff, difference

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing first treatment listed with second treatment listed

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing first treatment listed with second treatment listed

Bold words signify statistical significance P<0.05

* The same LDRBT+EBRT group was compared to EBRT (IMRT) or LDRBT group

Table D6 Urinary and bowel dysfunction scores: combination of radiation therapies vs. EBRT or LDRBT

Author Year [UI] Country | Outcome | Intervention | Follow -up, yr | No. Analyzed | Baseline | Change (SD) | Net diff | 95%CI | P btw | Quality
Song 2008 18714275 US | 4 month IPSS | EBRT (IMRT) + LDRBT | 0.33 | 15 | nd | 12.0 (8.0)^A^ | 2.5 | nd | 0.39 | C
Song 2008 18714275 US | 4 month IPSS | LDRBT | 0.33 | 15 | nd | 9.5 (7.0)^A^
Lev 2009 18719947 US | PSSR Urinary Score | EBRT (IMRT) + HDRBT | 1 | 49 | 26.70 | 2.79 (19.34) | −6.19 | −13.6, 1.25 | 0.10 | B
Lev 2009 18719947 US | PSSR Urinary Score | EBRT (IMRT) + LDRBT | 1 | 61 | 17.00 | 8.98 (19.7)
| PSSR Bowel Score | EBRT (IMRT) + HDRBT | 1 | 49 | 10.22 | 5.25(14.36) | 0.52 | −4.92, 5.96 | 0.85
| PSSR Bowel Score | EBRT (IMRT) + LDRBT | 1 | 61 | 7.6 | 4.73 (14.3)

nd, no data or not done; IPSS, International Prostate Symptom Score (range, in which higher scores indicate increased dysfunction); PSSR, Prostate Symptom Self Report (range from 0–100, in which higher scores indicate greater symptom unpleasantness)

A Value is IPSS score at four months

Figure D1 Genitourinary and gastrointestinal toxicity: combination of radiation therapies vs. EBRT or LDRBT

*Wong (2009) compared LDRBT+EBRT to either EBRT or LDRBT.