# Detailed results for the comparison between LDRBT vs. EBRT; HDRBT vs. LDRBT

## LDRBT vs. EBRT

(Tables C1–C8; Figures C1–C2)

### Randomized controlled trials (RCTs)

There were no randomized controlled trials comparing LDRBT versus EBRT for the treatment of localized prostate cancer that met our inclusion criteria.

### Prospective studies

(Table C1)

Four prospective cohort studies in five publications reported comparisons between LDRBT and EBRT. 23, 24, 59–61 The sample size in these studies ranged from 168 to 598. Two studies included only patients with T1 or T2 disease; 23, 61 two studies also included patients with T3 or higher stage disease (ranged from 0.83% to 2.3%).24, 59, 60 In addition, three studies included patients who also received some form of ADTs (ranged from 17% to 39%). The methodological quality of two studies were rated B and two were rated C. Some of the deficiencies in these studies included failure to adjust for potential confounders and large proportion of patients (>20%) lost to follow-up.

#### Biochemical control or patient survival

None of the studies provided data on biochemical outcomes or patient survival.

#### Genitourinary toxicities

(Tables C2–C3)

Four studies reported outcomes on adverse events of the genitourinary system using different disease specific quality of life instruments such as EPIC 26 and EPIC 50 [score ranged from 0 (worst) - 100 (best)] as well as the AUA symptom score (score ranged from 0 (best) - 35 (worst)). 23, 24, 59–61

Two studies found worse urinary outcomes (e.g., increased urinary incontinence or obstruction) in the LDRBT arm compared with the EBRT arm. 23, 59, 60 The first study had a total sample size of 168 (N = 90 (LDRBT), N = 78 (EBRT)). 59, 60 The study reported worse outcomes in the LDRBT arm compared with EBRT arm (HR; 0.76 (95% CI 0.66 to 0.88), P <0.05). The second study had a total sample size of 598 (N=306 (LDRBT), N =292 (EBRT)). 23 The study found worse urinary incontinence and urinary irritation/obstruction in the LDRBT arm compared to the EBRT arm. A third study did not find significant difference between the two groups. 24

The fourth study (N = 92 (LDRBT), N = 190 (EBRT)) stratified patients by baseline urinary function into normal, intermediate, and poor baseline function.61 The study did not find any difference in urinary dysfunction between groups in patients with normal baseline function. Patients with intermediate baseline function had less urinary incontinence but more urinary obstruction/irritation in the LDRBT arm compared with patients in the EBRT arm. Patients with poor baseline function had more urinary obstruction/ irritation in the LDRBT arm compared with the EBRT arm.

#### Gastrointestinal toxicities

(Tables C4–C5)

Four prospective studies that met our inclusion criteria reported gastrointestinal toxicities. 23, 24, 59–61 Three studies did not find significant difference in gastrointestinal toxicity rates between groups,23, 59–61 one study found lower rates of gastrointestinal toxicities in the LDRBT arm compared to the EBRT arm.24

#### Sexual dysfunction

(Tables C6–7)

Four studies reported outcomes on sexual dysfunction using different disease specific quality of life instruments.23, 24, 59–61 All except one60 reported better outcomes in the LDRBT arm compared with the EBRT arm; it should be noted that in this study, 25.6% of patients in the LDRBT arm also received EBRT in addition to LDRBT.60

### Retrospective studies

(Table C8)

Nine retrospective cohorts compared LDRBT with EBRT.17, 19–22, 25, 62–64 The sample size in these studies ranged from 233 to 133,904. Only one study included exclusively patients with T1 or T2 disease who did not receive any form of ADTs.20 The other studies included some patients with T3 or higher stage disease (ranged from 4.3 % to 17.6%) and/or also received some form of ADTs (ranged from 20% to 30%).

#### Patient survival

Only one retrospective cohort study with a total sample size of 10,179 analyzed patient survival.17 The study used the SEER staging to classify patients with local/regional prostate cancer into a localized disease category and other patients into a distant disease category. The analysis did not include any patients who received ADTs and adjusted for age, race, tumor stage, Gleason score, pretreatment comorbidity, and treatment modalities. The study directly compared BT and EBRT with no treatment or no initial treatment but did not directly compare BT with EBRT. However, the study provided sufficient data to allow for comparisons between BT and EBRT monotherapy [N = 644 (LDRBT), N = 876 (EBRT)]. Our calculations showed that there was no statistically significant difference between the two groups in the 7-year disease-specific survival rates [adjRR: 0.68 (95%CI, 0.30 to 1.5)]. The methodological quality this study was rated B.

#### Biochemical control

(Figure C1)

Six studies reported outcomes of biochemical control using the Phoenix definition (PSA nadir plus 2 ng/mL),19–22, 63, 64 in the form of biochemical No Evidence of Disease (bNED) or Freedom from Biochemical Failure (FFBF) at 5 years (except for one which reported FFBF at 4 years20). These studies all used different EBRT techniques such as 3D-CRT and IMRT in their analyses and some included patients who received a combination of treatment modalities.

Two studies exclusively included patients who did not receive ADTs. The first study reported statistically non-significant lower biochemical control rates in the LDRBT arm compared with EBRT arm (actuarial estimates 93.5% vs. 99.5%; P = 0.09). 20 The second study essentially found little or no difference in the biochemical control rates in the LDRBT arm compared with the EBRT arm (96% vs. 95%;).19 The methodological quality of these studies were rated B.

Of the remaining four studies21, 22, 63, 64 that included some patients who received ADTs, two21, 22 found statistically significant results in favor of the LDRBT arm compared with the EBRT arm (95.2% vs. 84.7% ; P < 0.001;^21^ 94% vs. 74%; P < 0.0001,^22^ respectively). The third study reported higher biochemical control rates (81% vs. 64%; P <0.014),63 in univariate analysis comparing LDRBT (with or without ADT) with EBRT (without ADT). After adjustment for pretreatment PSA concentration, the difference was no longer significant (P = 0.07). The fourth study reported lower biochemical control rates (92%: 95 % CI, 86% to 96% vs. 93%; 95% CI, 86% to 97% ) in the LDRBT arm compared with the EBRT arm (estimated risk difference: −0.01; 95% CI, −0.07 to 0.06).64 The methodological quality of two studies were rated C and two were rated B. Common deficiencies in these studies include suboptimal reporting (e.g., discrepancies in reporting of results) and lack of adjustment for potential confounders.

#### Genitourinary toxicities

(Table C2; Figure C2)

Three studies reported outcomes on acute or late genitourinary RTOG ≥ grade 3 toxicities.20–22 The first study did not find statistical difference in the rate of acute genitourinary toxicities between LDRBT and EBRT (3.8% vs. 1.4%, P=0.176).20 However, this study reported higher rate of late genitourinary toxicity in the LDRBT arm compared with the EBRT arm (5.6% vs. 0.5%, P <0.006). A second study reported the prevalence rate of late grade 3 or grade 4 genitourinary/gastrointestinal toxicity was higher in the LDRBT arm compared with the EBRT arm (5.3% vs. 1.8%).21 The third study22 provided individual data for 4 arms (LDRBT, EBRT-3D CRT, EBRT- IMRT, and LDRBT + EBRT) but did not analyze the comparison between LDRBT with EBRT; our own calculations showed that there was no significant difference in acute genitourinary toxicities between the LDRBT arm and EBRT arm (RD 0.02; 95% CI −0.00 to 0.04). However, those patients who received LDRBT had worse late genitourinary toxicities than patients who received EBRT (RD 0.06; 95% CI 0.30 to 0.10).

One study reported urethral strictures and found worse outcomes in the LDRBT arm compared with the EBRT arm (7% vs. 0%).20 This result was statistically significant (RD 0.07; 95% CI 0.03 to 0.11).

#### Gastrointestinal toxicities

(Table C4; Figure C2)

Four studies reported outcomes on acute or late gastrointestinal toxicities RTOG ≥ grade 3. 20–22, 62 Comparing LDRBT with EBRT, the first study found lower rates of acute (0% vs. 0.5%, respectively) and late gastrointestinal toxicities (0% vs. 2.8%, respectively) in the LDRBT group;62 no statistical comparisons were reported specifically for the grade 3 or greater toxicity in this study. The second study found little or no difference in the rates of late gastrointestinal toxicities in the LDRBT arm compared with the EBRT arm (0.7% vs. 0%, P = 0.228).20 We analyzed the results of the third study and did not find statistically significant difference between the two groups in acute and late gastrointestinal toxicities.22 The fourth study reported that the prevalence rate of late grade 3 or grade 4 genitourinary/gastrointestinal toxicity was higher in the LDRBT arm compared with the EBRT arm (5.3% vs. 1.8%).21

#### Other adverse outcomes - incidence rate of bladder and rectal cancer

(Tables C2, C4)

One retrospective cohort study analyzed the post-treatment incidence of bladder and rectal cancer in men who received LDRBT (N = 22,889) versus those who received EBRT (N = 93,059).25 After more than 10 years of follow-up, the men in the LDRBT arm compared with men in the EBRT arm had lower rates of bladder (RR 0.72; 95% CI 0.59 to 0.87) and rectal cancer (RR 0.64; 95% CI 0.45 to 0.91). The methodological quality of this study was rated B.

Table C1 Characteristics of prospective cohort studies that compared LDRBT with EBRT

Author Year [UI] Country | Intervention or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Chen 2009 [19620493] USA | EBRT | 190 | 69(51–82) | White 95 Black/other nd | 100 | <10: 67 10–20: 23 >20: 10 | 4–6: 48 7: 35 8–10: 18 | nd | nd | nd | nd | nd | nd | C com-1
Chen 2009 [19620493] USA | BT | 92 | 64(47–77) | White 91 Black/other nd | 100 | <10: 92 10–20 8 >20 0 | 4–6: 78 7:21 8–10:1 | nd | nd | nd | nd | nd | nd
Ferrer 2008 [18325680] Spain | EBRT | 205 | 69.2 (5.5) | nd | 98.0 | 10.1 (7.9)^A^ | 6.0 (1.1)^A^ | 33.7 | 74.03 (SD4.3) | 1.8–2.0 daily; 5 d/wk | nd | 1.01 cm (SD 0.18) | 3D-treatment planning | B com-2 com-5
Ferrer 2008 [18325680] Spain | LDRBT | 275 | 66.9 (6.5) | nd | 100 | 6.9(2.3) A | 5.7(4.4) A | 31.6 | 144 (D90 152 Gy; V100% =93%) | nd | nd | nd
Litwin 2007 [17455209] Gore 2009 [19509365] USA | EBRT | 78 | 70.8 (7.3) | White 84.6 Non white 15.4 | 97.5 | 13.6 (21.6)A | 6.7 (1.0) A | 59 | 68–77 | 1.8–2.0 (90%–100% of the isodose line) | nd | nd | nd | C com-1
Litwin 2007 [17455209] Gore 2009 [19509365] USA | LDRBT (74.4%) or BT with EBRT (25.6%); stratified by risk | 90 | 68.4 (6.9) | White 78.9 Non white 21.1 | 97.8 | 10.6 (14.6) A | 6.2 (0.8) A | 23 | nd on BT; 45 EBRT | nd | nd | nd | nd
Sanda MG 2008 [18354103] USA | EBRT | 292 | 69 (45–84) | White 82 Black 16 Other/not reported 3 | 100 | <4: 16 4–10: 61 >10: 23 | 2–6: 44 7: 42 8–10: 14 | 30 | nd | nd | nd | nd | nd | B com-5
Sanda MG 2008 [18354103] USA | LDRBT | 306 | 65 (44–84) | White 85 Black 12 Other/not reported 4 | 100 | <4: 22 4–10: 71 >10: 7 | 2–6: 74 7: 25 8–10: 1 | 6 | nd | nd | Transperineal technique. | nd | nd

A Mean (standard deviation)

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Table C2 Genitourinary toxicity: LDRBT vs. EBRT (qualitative)

Outcome | Interventions or comparisons (total sample size) | | Findings | Quality
Prospective cohort studies
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Sanda (2008) | Worse | B
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Ferrer (2008) | No diff | B
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Litwin (2007) or Gore (2009) | Worse^A^ | C
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | Chen (2009): | | C
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with normal function at baseline | No diff
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with intermediate function at baseline | Better / Worse^B^
Disease-specific QoL: urinary scores | LDRBT (N=715) vs. EBRT (N=695) | - patients with poor function at baseline | Worse
Retrospective cohort studies
Acute GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Eade (2008) | No diff | B
Acute GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Wong (2009) | No diff | B
Late GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Eade (2008) | Worse | B
Late GU ≥ Grade 3 | LDRBT (N=383) vs. EBRT (N=800) | Wong (2009) | Worse | B
Urethral strictures | LDRBT (N=158) vs. EBRT (N=216) | Eade (2008) | Worse | B
Incidence of bladder cancer (>10 years of follow-up) | LDRBT (N=22889) vs. EBRT (N=93059) | Nieder (2008) | Better | B

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GU toxicity or other adverse outcomes, comparing LDRBT with EBRT

No diff: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GU toxicity and other adverse outcomes, comparing LDRBT with EBRT

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GU toxicity or other adverse outcomes, comparing LDRBT with EBRT

Bold words signify statistical significance P<0.05

A Based on the Hazard Ratio of returning to baseline UCLA urinary score comparing the two groups

B Better for urinary incontinence score, and worse for urinary obstruction or irritation score

Table C3 Urinary dysfunction scores: LDRBT vs. EBRT

Author Year [UI] Country | Outcome | Intervention | Follow up, yr | No. Analyze d | Baseline | Change (SD) | Net diff | 95% CI | P btw | Quality
Sanda 2008 [18354103] USA | EPIC-26 urinary incontinence score | LDRBT | 1 | 272 | 94^A^ | −7 (nd) | −6 | nd | nd | B
Sanda 2008 [18354103] USA | EPIC-26 urinary incontinence score | EBRT | 1 | 258 | 92^A^ | −1 (nd)
Sanda 2008 [18354103] USA | EPIC-26 urinary irritation or obstruction score | LDRBT | 1 | 272 | 90^A^ | −8 (nd) | −11 | nd | nd
Sanda 2008 [18354103] USA | EPIC-26 urinary irritation or obstruction score | EBRT | 1 | 258 | 87^A^ | +3 (nd)
Ferrer 2008 [18325680] Spain | EPIC-50 urinary score | LDRBT | 2 | 275 | 95.2 | +2.8 (12) | −0.60 | −2.63,1.43 | NS | B
Ferrer 2008 [18325680] Spain | EPIC-50 urinary score | EBRT | 2 | 205 | 96.4 | +2.2 (10)
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI urinary score | LDRBT (74.4%) or BT with EBRT (25.6%) | 2 | 90 | 90^A^ | −8 (nd) | HR: 0.76 | 0.66, 0.88 | <0.05^B^ | C
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI urinary score | EBRT | 2 | 78 | 93^A^ | −3 (nd)
Litwin 2007 [17455209] Gore 2009 [19509365] USA | AUA symptom index | LDRBT (74.4%) or BT with EBRT (25.6%) | 2 | 90 | 10^A^ | +3 (nd) | HR: 0.68 | 0.61, 0.78 | <0.05^C^
Litwin 2007 [17455209] Gore 2009 [19509365] USA | AUA symptom index | EBRT | 2 | 78 | 10^A^ | −1 (nd)
Chen 2009 [19620493] USA | PCSI urinary incontinence score | BT | 3 | 70 | Normal: 0 | +5.4 (nd) | −0.1 | nd | nd | C
Chen 2009 [19620493] USA | PCSI urinary incontinence score | BT | 3 | 8 | Intermediate: 28.9 | −13.8 (nd) | −11.7 | nd | nd | C
Chen 2009 [19620493] USA | PCSI urinary incontinence score | EBRT | 3 | 120 | Normal: 0 | +5.5 (nd)
Chen 2009 [19620493] USA | PCSI urinary incontinence score | EBRT | 3 | 34 | Intermediate: 30.5 | −2.1(nd)
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | BT | 3 | 36 | Normal: 9.0 | +5.7 (nd) | −0.6 | nd | nd
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | BT | 3 | 26 | Intermediate: 21.4 | −2.4 (nd) | −2.5 | nd | nd
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | BT | 3 | 13 | Poor: 29.4 | −3.4 (nd) | +4.1 | nd | nd
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | EBRT | 3 | 51 | Normal: 9.2 | +6.3 (nd)
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | EBRT | 3 | 63 | Intermediate: 21.3 | +0.3 (nd)
Chen 2009 [19620493] USA | PCSI urinary obstruction or irritation score | EBRT | 3 | 38 | Poor: 36.2 | −7.5 (nd)

Diff, difference; PCSI, Prostate Cancer Symptom Indices (range, 0–100) in which higher scores indicate worse outcomes; EPIC, Expanded Prostate Cancer Index Composite (range, 0–100) in which higher scores indicate better outcomes; UCLA PCI, University of California – Los Angeles Prostate Cancer Index (range, 0–100) in which higher scores indicate better outcomes; AUA symptom index, American Urological Association symptom index (range, 0–35) in which higher scores indicate worse outcomes

A Estimated value from the figure

B Based on the Hazard Ratio of returning to baseline UCLA urinary score comparing the two groups

C Based on the Hazard Ratio of returning to baseline AUA symptom index comparing the two groups

Table C4 Gastrointestinal toxicity: LDRBT vs. EBRT (qualitative)

Outcome | Interventions or comparisons (total sample size) | Study | Findings | Quality
Prospective cohort studies
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Sanda (2008) | No diff | B
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Ferrer (2008) | Better^A^ | B
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Litwin (2007) or Gore (2009) | No diff^B^ | C
Disease-specific QoL: bowel scores | LDRBT (N=709) vs. EBRT (N=681) | Chen (2009) | Better | C
Retrospective cohort studies
Acute GI ≥ Grade 3 | LDRBT (N=275) vs. EBRT (N=767) | Wong (2009) | No diff | C
Acute GI ≥ Grade 3 | LDRBT (N=275) vs. EBRT (N=767) | Lesperance (2008) | No diff | C
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Eade (2008) | No diff | B
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Wong (2009) | No diff | B
Late GI ≥ Grade 3 | LDRBT (N=433) vs. EBRT (N=979) | Lesperance (2008) | No diff | C
Incidence of rectal cancer (>10 years of follow-up) | LDRBT (N=22889) vs. EBRT (N=93059) | Nieder (2008) | Better | B

Better: net difference in urinary scores improved >1 point or statistically significant risk difference in increasing acute/late GI toxicity or other adverse outcomes, comparing LDRBT with EBRT

No difference: net difference in urinary scores within 1 point or no statistically significant risk difference in acute/late GI toxicity and other adverse outcomes, comparing LDRBT with EBRT

Worse: net difference in urinary scores worsen >1 point or statistically significant risk difference in decreasing acute/late GI toxicity or other adverse outcomes, comparing LDRBT with EBRT

Bold words signify statistical significance P<0.05

A Adjusted for pretreatment score, age at diagnosis, risk group and hormonal treatment using generalized equation models

B Based on the Hazard Ratio of returning to baseline UCLA bowel score comparing the two groups

Table C5 Bowel dysfunction scores: LDRBT vs. EBRT

Author Year [UI] Country | Outcome | Intervention | Follow up, yr | No. Analyzed | Baseline | Change (SD) | Net diff | 95%CI | P btw | Quality
Sanda 2008 [18354103] USA | EPIC-26 bowel or rectal score | LDRBT | 1 | 272 | 96^A^ | −4 (nd) | 0 | nd | nd | B
Sanda 2008 [18354103] USA | EPIC-26 bowel or rectal score | EBRT | 1 | 258 | 94^A^ | −4 (nd)
Ferrer 2008 [18325680] Spain | EPIC-50 bowel score | LDRBT | 2 | 275 | 96.9 | +1.0 (5.9) | 3.6 | 2.04, 5.16 | <0.05^B^ | B
Ferrer 2008 [18325680] Spain | EPIC-50 bowel score | EBRT | 2 | 205 | 97.1 | −2.6 (11)
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI bowel score | LDRBT (74.4%) or BT with EBRT (25.6%) | 2 | 90 | 84^A^ | −5 (nd) | HR: 0.91 | 0.83, 1.01 | NS^C^ | C
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI bowel score | EBRT | 2 | 78 | 85^A^ | −5 (nd)
Chen 2009 [19620493] USA | PCSI bowel problem | BT | 3 | 42 | Normal: 0 | +5.4 (nd) | −1.1 | nd | nd | C
Chen 2009 [19620493] USA | PCSI bowel problem | BT | 3 | 30 | Intermediate: 7.5 | +1.9 (nd) | −2.1 | nd | nd | C
Chen 2009 [19620493] USA | PCSI bowel problem | EBRT | 3 | 64 | Normal: 0 | +6.5 (nd)
Chen 2009 [19620493] USA | PCSI bowel problem | EBRT | 3 | 76 | Intermediate: 6.8 | +4.0 (nd)

Diff, difference; PCSI, Prostate Cancer Symptom Indices (range, 0–100) in which higher scores indicate worse outcomes; EPIC, Expanded Prostate Cancer Index Composite (range, 0–100) in which higher scores indicate better outcomes; UCLA PCI, University of California – Los Angeles Prostate Cancer Index (range, 0–100) in which higher scores indicate better outcomes

A Estimated value from the figure

B Adjusted for pretreatment score, age at diagnosis, risk group, and hormonal treatment using generalized estimating equations models

C Based on the Hazard Ratio of returning to baseline UCLA bowel score comparing the two groups

Table C6 Sexual Dysfunction: LDRBT vs. EBRT (qualitative)

Author Year [UI] Country | Outcome | Intervention | Follow -up, yr | No. Analyzed | Net function: better, no diff, or worse | P btw | Quality
Sanda 2008 [18354103] USA | EPIC-26 sexual score | LDRBT | 1 | 272 | Better | nd | B
Sanda 2008 [18354103] USA | EPIC-26 sexual score | EBRT | 1 | 258
Ferrer 2008 [18325680] Spain | EPIC-50 sexual score | LDRBT | 2 | 275 | Better | <0.05^A^ | B
Ferrer 2008 [18325680] Spain | EPIC-50 sexual score | EBRT | 2 | 205
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI sexual score | LDRBT (74.4%) or BT with EBRT (25.6%) | 2 | 90 | Worse | <0.05^B^ | C
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI sexual score | EBRT | 2 | 78
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 26 | Better | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 29 | Better | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 20 | Better | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 31
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 39
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 80

PCSI, Prostate Cancer Symptom Indices (range, 0–100) in which higher scores indicate worse outcomes; EPIC, Expanded Prostate Cancer Index Composite (range, 00–100) in which higher scores indicate better outcomes; UCLA PCI, University of California – Los Angeles Prostate Cancer Index in which higher scores indicate better outcomes

Better: net difference in function scores improved >1 point

No diff: net difference in function scores within 1 point

Worse: net difference in function scores worsen >1 point

Bold words signify statistical significance P<0.05

Adjusted for pretreatment score, age at diagnosis, risk group, and hormonal treatment using generalized estimating equations models

Based on the Hazard Ratio of returning to baseline UCLA PCI sexual score comparing the two groups

Table C7 Sexual dysfunction scores: LDRBT vs. EBRT

Author Year [UI] Country | Outcome | Intervention | Follow up, yr | No. Analyzed | Baseline | Change (SD) | Net diff | 95%CI | P btw | Quality
Sanda 2008 [18354103] USA | EPIC-26 sexual score | LDRBT | 1 | 272 | 67^A^ | −6 (nd) | +4 | nd | nd | B
Sanda 2008 [18354103] USA | EPIC-26 sexual score | EBRT | 1 | 258 | 62^A^ | −10 (nd)
Ferrer 2008 [18325680] Spain | EPIC-50 sexual score | LDRBT | 2 | 275 | 48.6 | +1.2 (21) | +7.9 | 3.5, 12.3 | <0.05^B^ | B
Ferrer 2008 [18325680] Spain | EPIC-50 sexual score | EBRT | 2 | 205 | 50.2 | −6.7 (28)
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI sexual score | LDRBT (74.4%) or BT with EBRT (25.6%) | 2 | 90 | 40^A^ | −10 (nd) | HR: 0.82 | 0.69, 0.97 | <0.05^C^ | C
Litwin 2007 [17455209] Gore 2009 [19509365] USA | UCLA PCI sexual score | EBRT | 2 | 78 | 40^A^ | −12 (nd)
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 26 | Normal: 1.9 | +18.8 (nd) | −21.4 | nd | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 29 | Intermediate: 23.7 | +32.1 (nd) | −6.9 | nd | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | BT | 3 | 20 | Poor: 73.8 | −0.8 (nd) | −4.3 | nd | nd | C
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 31 | Normal: 2.1 | +40.2 (nd)
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 39 | Intermediate: 25.8 | +39.0 (nd)
Chen 2009 [19620493] USA | PCSI sexual dysfunction score | EBRT | 3 | 80 | Poor: 80.7 | +3.5 (nd)

Diff, difference; PCSI, Prostate Cancer Symptom Indices (range, 0–100) in which higher scores indicate worse outcomes; EPIC, Expanded Prostate Cancer Index Composite (range, 0–100) in which higher scores indicate better outcomes; UCLA PCI, University of California – Los Angeles Prostate Cancer Index in which higher scores indicate better outcomes

A Estimated value from the figure

B Adjusted for pretreatment score, age at diagnosis, risk group, and hormonal treatment using generalized estimating equations models

C Based on the Hazard Ratio of returning to baseline UCLA PCI sexual score comparing the two groups

Table C8 Characteristics of retrospective cohort studies that compared LDRBT with EBRT

Author Year [UI] Country | Intervention or comparison | N | Mean or Median, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Eade 2008 [18207665] USA | EBRT | 216 | 67.6 (26.7–80.6) | nd | 100 | 5.2 (0.4–9.6)^A^ | ≤6: 100 | 0 | 74–78 | 2.0 daily | α-cradle (Smithers Med Prod, Inc.) for simulation | 0.5–0.6 cm posterior; 0.8 cm all other directions | Step-and-shoot inverse planning (Corvus) | B
Eade 2008 [18207665] USA | LDRBT | 158 | 64.7 (42.0–78.3) | nd | 100 | 5.2 (0.5–9.8)^A^ | ≤6: 100 | 0 | 145 (8 pts had 160) | nd | nd | 0.3–0.5 cm | Variseed software (Varian)
Gondi 2007 [17382161] USA | BT +/ EBRT +/ ADT | 72 (21 BT alone, 51 with EBRT,) | nd | nd | 100 | ≤10 75 >10 25 | 2–6: 26 7: 74 | 11 ADT 12 EBRT+ADT | 66–70.6 Gy (ASTRO) | nd | nd | 1cm margins | nd | C com-2
Gondi 2007 [17382161] USA | SD-EBRT No ADT | 141 | nd | nd | 100 | ≤10: 74 >10: 26 | 2–6: 52 7: 48 | nd | 45Gy + BT boost after EBRT | | nd | nd | nd
Gondi 2007 [17382161] USA | SD EBRT with ADT | 84 | nd | nd | 100 | ≤10: 55 >10: 45 | 2–6: 20 7: 80 | nd | | nd | nd | nd | nd
Jabbari S 2010 [19409729] USA | LDRBT (57% BT alone, 7% EBRT,) low risk subset | 134 | 63 (43–78) | nd | 100 | 5.9: (0.4–9.7)^A^ | <6: 100 7: 0 8–10: 0 | 31 ADT 5 ADT+EBRT | 144Gy for I-125 or 125 Gy for pd | nd | nd | nd | nd | C com-5
Jabbari S 2010 [19409729] USA | EBRT (100% EBRT) Low risk subset | 124 | 70 (55–86) | nd | 100 | 6.4: (0.4–9.5)^A^ | <6: 100 7: 0 8–10: 0 | | 63–79 | 1.8 Gy | Static field conformal technique | nd | Preoperative forward planning
Jabbari S 2010 [19409729] USA | LDRBT (47% BT alone, 12% EBRT,) | 206 | 63 (43–78) | nd | 100 | 6.3: (0.4–14.7)^A^ | <6: 83.5 7: 16 8–10: 0.5 | 28 ADT 13 ADT+EBRT | nd | nd | nd | nd
Lesperance 2008 [18374892] USA | EBRT | 183 | 68.2 (48–84) | White 66.6 Black 23 Other 10.4 | 76 | nd | 5–7: 79 8–10: 19 | 38 | 64–76 | 1.8 | nd | nd | Treatment planning CT | C com-6
Lesperance 2008 [18374892] USA | LDRBT | 50 | 63 (47–98) | White 72 Black 16 Other 12 | 96 | nd | 5–7: 82 8–10: 2 | 16 | (12 pts received 46 Gy EBRT boost) | nd | nd | nd | nd
Nieder 2008 [18801517] USA | EBRT | 93059 | 40–49: 0.65 50–59: 7.46 60–69: 31.93 70–79: 52.56 80+: 7.40 | White 81.59 Black 12.51 Other 5.91 | 51.23 | nd | 2–4: 9 5–7: 64.01 8–10: 22.47 Unknown: 4.53 | nd nd | nd | nd | nd | nd | nd | B
Nieder 2008 [18801517] USA | LDRBT | 22889 | 40–49: 1.28 50–59: 16.12 60–69: 41.10 70–79: 38.28 80+: 3.22 | White 88.17 Black 8.42 Other 3.41 | 62.87 | nd | 2–4: 5.84 5–7: 83.52 8–10: 7.04 Unknown: 3.6 | | nd | nd | nd | nd | nd
Nieder 2008 [18801517] USA | EBRT + LDRBT | 17956 | 40–49: 1.50 50–59: 15.52 60–69: 39.94 70–79: 40.08 80+: 2.96 | White 82.33 Black 13.77 Other 3.90 | 57.31 | nd | 2–4: 4.96 5–7: 69.22 8–10: 22.64 Unknown: 3.17 | nd | nd | nd | nd | nd | nd
Pe ML 2009 [19376564] USA | EBRT LDRBT | 189 171 | 70(49–83) 65(42–78) | White 77.7 Black 18.3 Other 4.1 White 85 Black 9.3 Other 5.2 | 100 100 | 6.5: (0.6–9.9)^A^ 5.7: (0.8–9.8)^A^ | nd nd | 0 0 | 73.8 145 | nd nd | nd nd | nd 3–5mm | nd nd | B
Pickles T 2010 [19570619] Canada | EBRT | 139 | 71 (54–84) | nd | 100 | 5.6^A^ | 2–6: 87.8 7: 12.2 | 30.2 31.7 | 55.2–72 | nd | nd | 1–1.5 cm | CT imaging without daily image guidance | B
Pickles T 2010 [19570619] Canada | LDRBT | 139 | 64 (48–79) | nd | 100 | 6.4^A^ | 2–6: 87.8 7: 12.2 | | 144 | nd | nd | nd | real-time 0.33 mCi (NIST99) of I-125 sources (model 6711; (Oncura)
Wong 2009 [19670452] USA | EBRT(3D CRT) | 270 | nd | | 90 | ≤10: 71 10.1–20: 19 ≥20: 10 | ≤6: 65 | 28 | 45 Gy | 1.8 to 2 | nd | 1.0 to 2.0 cm | none | B
Wong 2009 [19670452] USA | EBRT(IMRT) | 314 | nd | | 96 | ≤10: 76 10.1–20: 17 ≥20: 7 | ≤6: 44 | | Median dose of 75.6 Gy | nd | nd | 6 to 10 mm | CT
Wong 2009 [19670452] USA | LDRBT | 225 | nd | | 100 | ≤10: 86 10.1–20: 12 ≥20: 2 | ≤6: 77 | 32 | 144 Gy for I-125 and 120 Gy for pd-103 | n/a | nd | n/a | nd
Wong 2009 [19670452] USA | EBRT+LDRBT | 44 | nd | | 98 | ≤10: 65 10.1–20: 30 ≥20: 5 | ≤6: 45 | 27 | 45 Gy | nd | nd | nd | nd
Zhou EH 2009 [18538495] USA | EBRT | 876 | | White or other 90.1 Black 9.9 | | nd | <7: 76.9 7–10: 15.4 Unknown: 7.7 | 0 | nd | nd | nd | nd | nd | B com-1
Zhou EH 2009 [18538495] USA | BT | 644 | | White or other 94.5 Black 5.5 | | nd | <7: 82.4 7–10: 8.2 Unknown: 9.4 | 0 | nd | nd | nd | nd | nd
Zhou EH 2009 [18538495] USA | NT | 2306 | | White or other 89.3 Black 10.6 | | nd | <7: 70.12 7–10: 14.6 Unknown: 15.3 | 0 | nd | nd | nd | nd | nd

A Median (range)

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

nd: no data provided

Figure C1 Freedom from biochemical failure (5 years of follow-up): LDRBT vs. EBRT

*Gondi (2007) comparing BT (with or without ADT) with EBRT (without ADT).

Figure C2 Genitourinary and gastrointestinal toxicity: LDRBT vs. EBRT*

*Studies that reported continuous outcomes for GU and GI toxicity (e.g., urinary score and bowel score) are not included in this figure. The detailed results for these studies are summarized in Tables C3 and C5.

## LDRBT vs. HDRBT

(Table C9; Figure C3)

We did not identify any eligible RCTs or prospective cohort studies for this comparison. One retrospective study reported the combined experience from 2 centers comparing HDR using Ir-192 (38 Gy or 42 Gy) with LDR using Pd-103 (120 Gy).26 A total of 454 participants were evaluated. All had either T1 or T2 disease. Up to one-third of the participants had some form of ADTs. There was no difference in the 5-year freedom from biochemical failure in the two groups (88% in HDR vs. 89% in LDR; P = 0.62). In terms of morbidity comparing HDR with LDR, acute (< 6 months) genitourinary toxicity ≥ grade 3 was 4.5% versus 14.5%; for chronic (> 6 months) genitourinary toxicity ≥ grade 3, it was 9% versus 8.5%; for acute gastrointestinal toxicity ≥ grade 3, it was 0% versus 0.5%; and for chronic gastrointestinal toxicity, it was 0.5% versus 2%. No P values were provided for these comparisons. The proportion of patients with impotency at 5 years did not differ between groups (20% in HDR vs. 30% in LDR; P = 0.23). It should be noted that the treatment techniques evolved over time in the two groups. The methodological quality of this study was rated C because there was no statistical adjustment for potential confounders.

Table C9 Characteristics of retrospective cohort studies that compared HDRBT with LDRBT

Author Year [UI] Country | Intervention(s) or comparison | N | Mean age, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality Comments
Martinez 2009 [19952715] US | HDRBT (Ir-192) A | 259 | 64 | nd | 100 | ≤3.9: 16 4–9.9: 80 >10: 4 B | ≤5 8 6 83 >7 9 | 27 | 38; 42 | 9.5; 7 | nd | 150% isodose line not touching urethra | U/S or real time (Oncentra-prostate) | C com-1
Martinez 2009 [19952715] US | LDRBT (Pd^103^) B | 206 | 66 | nd | 100 | ≤3.9: 19 4–9.9: 76 >10: 5 | ≤5 18 6 75 >7 7 | 31 | 120 | nd | nd | nd | U/S or real time (Oncentra-prostate)

A estimated, discrepancy in CET data in Table 1 in paper

B procedure evolved over the study years; 2 centers had different procedures

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Figure C3 Genitourinary and gastrointestinal toxicity: HDRBT vs. LDRBT