# Detailed results for the comparison between radiation therapy and no treatment or no initial treatment

## Key Question 1 What are the benefits and harms of radiation therapy for clinically localized prostate cancer compared to no treatment or no initial treatment (watchful waiting, active surveillance, or observation) in terms of clinical outcomes?

### Randomized controlled trials (RCTs) and Prospective studies

We did not identify eligible RCTs or prospective cohort studies that compared the benefits and harms in radiation therapy versus no treatment or no initial treatment.

### Retrospective studies

(Table B1)

Five retrospective cohorts reported comparisons between radiation therapy and watchful waiting.14–18 One study included only patients with T1 or T2 disease,15 while the other four studies included some patients with T3 or higher stage disease. One study did not specify patients’ T stage, but included only patients with localized disease.16

#### Patient survival

(Figure B1)

Of the four analyses reported in three registry studies that compared survival between observation and radiation therapy,15–17 one found lower disease-specific mortality rates in radiation therapy patients compared with patients with no treatment or no initial treatment. In the Ohio CALD study that included patients with local/regional cancer on BT (N = 595), EBRT (N = 783), or no treatment or no initial treatment (N = 1716), compared with patients without treatment (or without initial treatment), disease-specific mortality rates were significantly lower among patients who received BT [adjHR: 0.45 (95%CI, 0.23 to 0.87)], and non-significantly lower among those who received EBRT [adjHR: 0.66 (95%CI, 0.41 to 1.04)], after adjusting for age, race, tumor stage, Gleason score, pretreatment comorbidity, and treatment modalities. 17 The Connecticut Tumor Registry study that analyzed 816 patients with T1 or T2 prostate cancer reported that patients in the observation arm had a non-significant greater prostate cancer mortality rate compared with patients who received EBRT [adjHR: 1.5 (95%CI, 0.9 to 2.6)], after adjusting for age at diagnosis, pretreatment Gleason score, PSA, clinical stage, and Charlson comorbidity score. 15 Similarly, in the Henry Ford Health System tumor registry, disease-specific mortality rates were non-significantly lower among patients on radiation therapy (N = 137) compared with patients on watchful waiting (N = 197) [adjHR: 0.64 (95%CI, 0.38 to 1.06); P = 0.081], after adjusting for race, age at diagnosis, socioeconomic status, Charlson score, year of diagnosis. 16 The methodological quality of all three retrospective studies were rated B.

#### Genitourinary toxicity

A study based on the CaPSURE™ database with 2.7 year follow-up of prostate cancer patients who had watchful waiting (N = 378), EBRT (N = 645), BT (N = 799) or combined EBRT and BT (N = 231) reported that patients on the combined therapy had a significantly higher rate of receiving urethral stricture treatment compared with patients on watchful waiting, after adjusting for age at primary treatment and BMI [adjHR: 4.56 (95%CI, 1.23 to 16.88)]. 18 There was no difference between watchful waiting and EBRT or watchful waiting and BT. The methodological quality of this study was rated B. The number of patients lost to follow-up was unclear.

#### Other adverse outcome - second primary cancer

A report based on the Surveillance, Epidemiology, and End Results (SEER) database compared patients who had watchful waiting (N = 40,733), EBRT (N = 48,400), BT (N = 10,233) or combined EBRT and BT (N = 9,096).14 Compared to patients in the watchful waiting arm, those who received EBRT had a significantly higher rate of second primary cancer (adjHR: 1.14; 95%CI, 1.09 to 1.19) and late second primary cancer (after ≥ 5 years) (adjHR: 1.26; 95%CI, 1.17 to 1.37), after adjusting for age at prostate cancer diagnosis, race/ethnicity, and grade of primary prostate cancer. There was no difference between watchful waiting and BT or combined therapy. The methodological quality of this study was rated B.

Table B1 Characteristics of retrospective cohort studies that compared radiation therapy with no treatment or no initial treatment

Author Year [UI] Country | Intervention or comparison | N | Mean age, yr | Race, % | T1 or T2, % | PSA (ng/mL), % | Gleason score, % | ADT, % | Total Dose (Gy) | Dose per fraction (Gy) | Immobilization technique | Applied margins for PTV | Planning algorithm | Quality comments
Abdel-Wahab M 2008 [18374503] US | Radiation therapy (BT, EBRT, or BT + EBRT) | 67719 | 69.4 | Hispanic White 4.9 Non Hispanic White 76.8 Non-Hispanic Black 11.7 Other non-Hispanic 6.5 | 82.1 | nd | nd | nd | nd | nd | nd | nd | nd | B
Abdel-Wahab M 2008 [18374503] US | Watchful waiting | 40733 | 73.1 | Hispanic White 7.0 Non Hispanic White 72.9 Non-Hispanic Black 13.3 Other non-Hispanic 6.8 | 78.1 | nd | nd | nd | nd | nd | nd | nd | nd
Albertsen 2007 [17296379] US | EBRT | 702 | 71 | nd | 100 | 0-3.9: 27 4-9.9: 44 10-10: 17 20-49: 12 | 2-4: 17 5: 15 6: 46 7: 11 8-10: 11 | nd | nd | nd | nd | nd | nd | B
Albertsen 2007 [17296379] US | Observation | 114 | 70 | nd | 100 | 0-3.9: 9 4-9.9: 39 10-10: 29 20-49: 23 | 2-4: 3 5: 6 6: 46 7: 25 8-10: 20 | nd | nd | nd | nd | nd | nd
Elliott 2007 [17570425] US | Watchful waiting, BT, EBRT, BT + EBRT | 6597^C^ | >60yr 25 60-69 40 ≥ 70 35 | White 87 Black 9 Other 4 | 98 | ≤4: 14 4.1-10: 62 10.1-20: 16 >20: 8 | 2-6: 65 7: 26 8-10: 9 | nd | nd | nd | nd | nd | nd | B com-2
Tewari 2007 [17296374] US | Radiation | 137 | 53.5 | White 54.0 Black 46.0 | nd | nd | nd | 26 | nd | nd | nd | nd | nd | B
| Watchful waiting | 197 | 52.1 | White 46.2 Black 53.8 | nd | nd | nd | 80 | nd | nd | nd | nd | nd
Zhou 2009 [18538495] US | EBRT, BT, no treatment or no initial treatment^A^ | 10179^D^ | 60-69 21.5 70-74 32.1 ≥ 75 46.5 | White or other 91 Black 9 | nd | nd^B^ | <7: 66.4 7-10: 23.8 Unknown: 9.8 | nd | nd | nd | nd | nd | nd | B

nd, no data or not done

A No treatment or no initial treatment was defined as no definitive therapy within 6 months of the prostate cancer diagnosis

B Tumor was categorized as local-regional in 81.1% of patients, distant metastases 4.6% of patients, and unknown in 14.3% of patients

C Including 3310 surgery patients, 199 cryosurgery patients, 73 surgery and EBRT patients, and 961 ADT patients

D Including 936 surgery patients, 2947 ADT only patients, and 4776 combination therapy patients

com-1: No adjustment for potential confounders

com-2: incomplete reporting (e.g., little or no description of study eligibility criteria or methods, missing data)

com-3: historical comparison

com-4: incomplete statistical analysis (e.g., P value not reported)

com-5: different lengths of follow-up between groups

com-6: baseline participant characteristics not entirely comparable between groups (no adjustment)

com-7: loss to follow-up ≥20% (only for RCTs)

com-8: method of randomization not reported

Figure B1 Patient survival: radiation therapy vs. no treatment or no initial treatment

* No treatment or no initial treatment was defined as no definitive therapy within 6 months of the prostate cancer diagnosis