# Search Strategy

Prostate cancer and Radiotherapy

EBM (RCT, HTA, SR), and MEDLINE (1950–2009, in process) 5^th^ Jan 2010

# | Search strategy
1 | randomized controlled trial.pt.
2 | controlled clinical trial.pt.
3 | randomized controlled trials/
4 | Random Allocation/
5 | Double-blind Method/
6 | Single-Blind Method/
7 | clinical trial.pt.
8 | Clinical Trials.mp. or exp Clinical Trials/
9 | (clinic$ adj25 trial$).tw.
10 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw.
11 | Placebos/
12 | placebo$.tw.
13 | random$.tw.
14 | trial$.tw.
15 | (randomized control trial or clinical control trial).sd.
16 | (latin adj square).tw.
17 | Comparative Study.tw. or Comparative Study.pt.
18 | exp Evaluation studies/
19 | Follow-Up Studies/
20 | Prospective Studies/
21 | (control$ or prospectiv$ or volunteer$).tw.
22 | Cross-Over Studies/
23 | or/1-22
24 | exp prostatic neoplasms/
25 | exp radiotherapy/
26 | *"Prostatic Neoplasms"/rt [Radiotherapy]
27 | (act$ adj3 surve$).mp.
28 | (watch$ adj3 wait$).mp.
29 | Intensity modulated$.mp. [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
30 | charged particle beam$.mp. [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
31 | brachytherapy/
32 | radiation therap$.mp. [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
33 | stereotactic radiosurger$.mp. [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
34 | conformal radiotherap$.mp. [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
35 | exp radiosurgery/
36 | 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35
37 | 24 and 36
38 | 23 and 37
39 | limit 38 to english language [Limit not valid in CDSR,CCTR; records were retained]
40 | limit 39 to yr="2007 -Current"
41 | remove duplicates from 40
42 | prostate cancer.mp. or exp prostatic neoplasms/ [mp=ti, ot, ab, nm, hw, ui, tx, kw, ct, sh]
43 | 23 and 42
44 | 36 and 43
45 | limit 44 to english language [Limit not valid in CDSR,CCTR; records were retained]
46 | limit 45 to yr="2007 -Current"
47 | 46 not 41

Cyberknife search: Ovid MEDLINE(R) 1950 to January Week 4 2010

# | Search strategy
1 | cyberknife.mp.
2 | prostatic neoplasms.mp. or exp Prostatic Neoplasms/
3 | 1 and 2