# Abbreviations

2D-RT: conventional (non-3D planned) RT
3D-CRT: conformal RT
ADT: androgen deprivation therapy
AUA: American Urological Association
bDFS: biochemical (PSA) disease free survival
BED: biological effective dose
bNED: Biochemical no evidence of disease; same as bDFS
BT: Brachytherapy
CRT-PO: conformal RT prostate only
EBRT: external beam RT (including 2D-RT, 3D-CRT, IMRT)
FFBF: freedom from biochemical failure
Gy: Gray (unit of radiation dose)
GyE: Gray equivalents (used for particle therapy dose reporting)
HDR or HDRBT: high dose rate brachytherapy
IGRT: image guided RT (including IMRT and SBRT)
IMRT: intensity modulated RT
LDR or LDRBT: low dose rate brachytherapy
nADT: Neo-adjuvant androgen deprivation therapy
NCCN: National Comprehensive Cancer Network
NCI: National Cancer Institute
NT: No treatment or no initial treatment
PSA: Prostate-specific antigen
PT: proton or particle therapy
QoL: quality of life
PPI: Permanent Prostate Implant Brachytherapy
RT: radiation therapy
RTOG: Radiation Therapy Oncology Group
SBRT: stereotactic body RT
SEER: Surveillance, Epidemiology, and End Results Program of the NCI
TURP: transurethral resection of the prostate
WW: watchful waiting