# Executive Summary

## Background

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Tufts EPC (Contract No. 290 2007 10055 I).

Prostate cancer is the most common noncutaneous malignancy diagnosed in men in the United States. The vast majority of patients diagnosed today have clinically localized prostate cancer (T1-T2N0), which is the subject of this report. A Comparative Effectiveness Review of Therapies for Clinically Localized Prostate Cancer was undertaken on behalf of the Agency for Healthcare Research and Quality (AHRQ) by the Minnesota Evidence-based Practice Center (EPC) in 2007 (Wilt et al. Comparative effectiveness of therapies for clinically localized prostate cancer. Comparative Effectiveness Review No. 13, prepared by Minnesota Evidence-based Practice Center under contract no. 290-02-0009 Rockville, MD: Agency for Healthcare Research and Quality, February 2008. Available at effectivehealthcare.ahrq.gov/reports/final.cfm). The report concluded that “No one therapy can be considered the preferred treatment for localized prostate cancer due to limitations in the body of evidence as well as the likely tradeoffs an individual patient must make between estimated treatment effectiveness, necessity, and adverse effects. All treatment options result in adverse effects (primarily urinary, bowel, and sexual), although the severity and frequency may vary between treatments. Even if differences in therapeutic effectiveness exist, differences in adverse effects, convenience, and costs are likely to be important factors in individual patient decision making.” As more studies on radiation treatments have been published since the Minnesota report, the Centers for Medicare and Medicaid Services (CMS) is interested in an update. After consultation with AHRQ and CMS, this technology assessment has been commissioned specifically to examine the recent comparative studies on radiation treatments of clinically localized prostate cancer.

## Methods

This report addressed the following key questions:

1. What are the benefits and harms of radiation therapy for clinically localized prostate cancer compared to no treatment or no initial treatment (watchful waiting, active surveillance, or observation) in terms of clinical outcomes?
2. What are the benefits and harms of different forms of radiation therapy for clinically localized prostate cancer in terms of clinical outcomes? The comparisons of interest are between the following radiation modalities: stereotactic body radiation therapy (SBRT, including CyberKnife® therapy), classically fractionated external beam radiation therapy (EBRT, including 3D-conformal radiation therapy, intensity modulated radiation therapy, and particle therapy), high dose rate brachytherapy (HDRBT), and low dose rate brachytherapy (LDRBT, including permanent brachytherapy).
3. How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbidities, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression) affect the outcomes of these different forms of radiation therapy?

We relied on findings from the 2008 comparative effectiveness review of therapies for clinically localized prostate cancer conducted by the Minnesota EPC as a springboard for our review. As the Minnesota review conducted its literature search through mid-September 2007, we conducted our literature search from January 2007 to ensure that all relevant and eligible studies are included. The methods for this technology assessment largely follows the methods suggested in the Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 published by AHRQ (available at effectiveheealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf).

We included randomized controlled trials and non-randomized direct comparative studies of men with clinically localized disease that reported clinical outcomes for T1 or T2 disease. We excluded single cohort studies, adjuvant, salvage, or post-prostatectomy radiation therapy studies, and studies evaluating androgen deprivation therapy. The intervention of interest was radiation treatment used as a first line treatment of prostate cancer. The treatments included various forms of external beam radiation therapy (intensity-modulated radiotherapy, conformal radiation, stereotactic body radiation including CyberKnife®, and proton beam), and brachytherapy (permanent seed implantation and high dose rate temporary brachytherapy). The treatments reviewed also included combination radiation therapies, such as external beam radiation therapy with brachytherapy boost. The comparators of interest were no treatment or no initial treatment (including watchful waiting and active surveillance) and alternate forms of radiation therapy. Outcomes of interest included overall and prostate cancer-specific survival, metastatic and/or clinical progression free survival, freedom from biochemical (PSA) failure, quality of life, bowel and urinary toxicities, and sexual dysfunction.

From the included studies, we extracted information on patient samples, radiation treatment characteristics (e.g., type of radiation (proton vs. photon), source of radiation (linear accelerator, Cobalt-60, internally planted radioactive seeds), dose, number of fractions, and manufacturer of device), treatment planning algorithm, outcomes (clinical and biochemical), adverse events, and study design. We used a 3-grade (A, B, C) rating system to rate the quality of the individual study. We also used a 3-category rating system (high, moderate, insufficient) to assess the overall strength of evidence for the outcomes reported in each of the comparisons.

## Results and Strength of Evidence

We searched for articles on radiation treatments for prostate cancer published between January 2007 and December 2009 in the MEDLINE® and Cochrane Central database and found 51 out of 1,283 articles that met our inclusion criteria. We also added 9 randomized controlled trials (RCTs) relevant to radiation treatments identified in the Minnesota report to our analysis. A total of 62 articles were included in our review. The table below summarized the strength of evidence for the outcomes reported in each of the comparisons.

Table 1 Strength of evidence for radiation treatments of clinically localized prostate cancer

| High | Moderate | Insufficient
KQ1. Radiation therapy versus no treatment or no initial treatment
Freedom from Biochemical failure | | | X^a^
Disease Specific Survival | | | X^b^
Genitourinary/Gastrointestinal Toxicity | | | X^c^
KQ 2. Different forms or doses of radiation
SBRT versus EBRT | | | X^a^
SBRT versus HDRBT | | | X^a^
SBRT versus LDRBT | | | X^a^
EBRT versus HDRBT | | | X^a^
EBRT versus LDRBT
Freedom from Biochemical failure | | | X^b^
Disease Specific Survival | | | X^c^
Genitourinary/Gastrointestinal Toxicity | | | X^b^
LDRBT versus HDRBT
Freedom from Biochemical failure | | | X^c^
Disease Specific Survival | | | X^c^
Genitourinary/Gastrointestinal Toxicity | | | X^c^
Combined RT modality comparisons
Freedom from Biochemical failure | | | X^c^
Genitourinary/Gastrointestinal Toxicity | | | X^d^
Intra SBRT comparisons
Freedom from Biochemical failure | | | X^c^
Genitourinary/Gastrointestinal Toxicity | | | X^c^
Intra EBRT comparisons
Freedom from Biochemical failure | | X^e^
Genitourinary/Gastrointestinal Toxicity | | X^e^
Intra BT comparisons
Freedom from Biochemical failure | | | X^f^
Genitourinary/Gastrointestinal Toxicity | | | X^b^
KQ 3. Patient characteristics related to radiation treatment outcomes
Baseline risk (Stage, PSA, Gleason score) | | | X^b^
Gleason score/PSA levels | | | X^c^

a No study available

b Results inconsistent across studies

c Only one study

d Predominantly C quality studies

e ≥2 B quality RCTs that reported similar results (significant difference or no difference)

f Only one RCT and one retrospective study

Key Question 1. What are the benefits and harms of radiation therapy for clinically localized prostate cancer compared to no treatment or no initial treatment (watchful waiting, active surveillance, or observation) in terms of clinical outcomes?

The strength of evidence for comparing radiation therapy with no treatment or no initial treatment was rated “insufficient” because available data were all provided by retrospective analyses. The Minnesota review did not identify any RCTs that compared external beam radiation therapy with no treatment or no initial treatment; neither did this update review. Data from three retrospective cohorts showed mostly non-significant improvement in disease-specific patient survival in those who received radiation therapy compared to those who had either no treatment or no initial treatment.

Key Question 2. What are the benefits and harms of different forms of radiation therapy for clinically localized prostate cancer in terms of clinical outcomes? The comparisons of interest are between the following radiation modalities: stereotactic body radiation therapy (SBRT,), classically fractionated external beam radiation therapy (EBRT, including 3D-conformal radiation therapy, intensity modulated radiation therapy, and particle therapy), high dose rate brachytherapy (HDRBT), and low dose rate brachytherapy (LDRBT, including permanent brachytherapy).

There were no comparisons between SBRT and any other radiation modality. There were also no comparisons between EBRT and HDRBT.

### LDRBT vs. EBRT

Evidence for the comparative efficacy between LDRBT and EBRT on patient survival was rated “insufficient” as there was only one eligible study in this comparison. This retrospective study suggests that there was no difference in disease specific patient survival comparing LDRBT with EBRT.

Evidence for the comparative efficacy between BT and EBRT on biochemical control was rated “insufficient” because the results were inconsistent across the four B-rated studies in this comparison. While two studies found better biochemical control in the LDRBT group compared to the EBRT group, two studies did not find differences between groups.

Evidence for the comparative efficacy between LDRBT and EBRT for genitourinary and gastrointestinal toxicities was rated “insufficient” because the four B-rated studies did not report consistent results. Two studies did and two studies did not show that LDRBT was associated with significantly more genitourinary toxicity than EBRT. For gastrointestinal toxicity, one study showed that LDRBT was associated with less gastrointestinal toxicity compared with EBRT, the other three studies did not find significant difference between LDRBT and EBRT.

Regarding sexual dysfunction, one study showed significantly better outcomes with LDRBT compared with EBRT, another study also reported better outcomes with LDRBT compared with EBRT but the P value of this study was not reported..

Only one study reported cancer incidence comparing LDRBT with EBRT; this study showed a significantly lower incidence of bladder and rectal cancer with LDRBT compared with EBRT.

### LDRBT vs. HDRBT

Evidence for the comparative efficacy between HDRBT and LDRBT on biochemical outcome was rated “insufficient” as only one retrospective study provided relevant data. Comparing HDRBT using Ir-192 (38 Gy or 42 Gy) with LDRBT using Pd-103 (120 Gy), this study did not find a difference in the 5-year freedom from biochemical failure in the two groups.

### Combination Therapies: LDRBT plus EBRT in different doses

Evidence on the comparative efficacy of different combinations of radiation was rated “insufficient”, as there were only a few studies in each of the comparisons.

One study did not find a difference in biochemical failure comparing LDRBT plus EBRT in different doses, while another study did not find a difference in biochemical failure comparing LDRBT plus EBRT versus LDRBT. One study did not find a difference in biochemical or clinical failure comparing EBRT with EBRT plus HDRBT.

Limited data suggest greater genitourinary toxicity in EBRT plus LDRBT versus EBRT, and BT plus EBRT versus EBRT.

Our analysis of the data from a study comparing EBRT plus BT versus EBRT showed a significantly increased rate of second primary cancers and late second primary cancers (≥ 5 years) in the EBRT arm.

In addition to comparing different modalities of radiation therapy with each other, we also reviewed comparative evidence within a given radiation modality.

### Intra-SBRT comparisons

Evidence for the comparative efficacy on SBRT was rated “insufficient” as only one study qualified for inclusion in this review. This retrospective study found little difference in bladder and rectal toxicities between those who received 35 Gy in 5 fractions and those who received 36.25 Gy also in 5 fractions.

### Intra-EBRT Comparisons

For EBRT dose comparison, “moderate” level of evidence from eight studies suggests that higher dose EBRT is associated with increased rates of freedom from biochemical failure at 5 to 10 years compared to lower dose EBRT.

Data from five studies suggest that there is little or no difference in acute and late genitourinary or gastrointestinal toxicities between higher and lower dose EBRT.

For EBRT fractionation comparison, data from three studies suggest that there is no difference between standard fractionation and hypofractionation arms as tested in the studies for freedom from biochemical failure. There is also little or no difference in gastrointestinal toxicity between arms. One B-rated RCT reported a slightly higher acute genitourinary toxicity in the hypofractionation arm compared with the standard fractionation arm, but there was no difference in late genitourinary toxicity.

### Intra-LDRBT comparisons

For LDRBT dose and radionuclide comparison studies, “insufficient” level of evidence from one RCT suggests there is little or no difference between I-125 (144 Gy) and Pd-103 (125 Gy) in terms of freedom from biochemical failure at 3 to 6 years. One analysis found that higher biological effective dose (BED) (>220 Gy) using either I-125 or Pd-103 may improve the 5-year rate of freedom from biochemical failure compared with lower dose (≤220 Gy) in those with higher risk of prostate cancer progression (Gleason score 8 to 10).

Key Question 3. How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbidities, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression) affect the outcomes of these different forms of radiation therapy?

There were few studies on the potential effects of different patient characteristics on treatment outcomes, apart from patients’ baseline risk. The strength of evidence for evaluating baseline risk as a modifier of outcomes of radiation therapies was rated “insufficient” because there were limited studies for the comparisons reviewed.

## Discussion

Because prostate cancer tends to have a long clinical course typically measured in decades, many studies focused on short term adverse events or biochemical control rather than long term clinical efficacy outcomes like metastases and disease-specific mortality. It should be noted that in the studies reviewed, the event rates for grade 3 or greater urinary or bowel toxicity are so low that any statistically significant differences between treatment arms may not translate into substantive clinical differences.

Many of the findings reported in this review were inconsistent for each of the outcomes of interest. The studies reviewed showed substantial heterogeneity. Even among patients with T1 or T2 prostate cancer, the underlying risk of prostate cancer progression varies widely. An important weakness in many of these comparative analyses is that patients were given treatments tailored to their individual risk profile (e.g., patients with low risk prostate cancer tend to be given BT versus those with intermediate risk prostate cancer tend to be given EBRT); this makes it difficult, if not impossible, to assess the comparative efficacies between two forms of radiation treatments as the underlying risk of prostate cancer progression in the two groups of patients may be fundamentally different.

The focus of this review is clinically localized prostate cancer (stages T1 and T2). The majority of the patients in these studies had clinically localized disease (stage T1 and T2); however, approximately one-third of the studies reviewed included up to 20% of patients with stage T3 or higher disease. Excluding them would lead to a drastically reduced number of qualified studies and may inadvertently discard useful data. Similarly, approximately half of the studies had some patients who received androgen deprivation therapies (ADTs), either as a neoadjuvant, concurrent or adjuvant therapy. Many of the studies that included patients with stage T3 or higher disease or ADTs did not report results stratified by patients’ tumor stage or ADT use. Therefore, we are not always able to draw conclusions on the specific treatment effects of the different forms of radiation alone for clinically localized prostate cancer patients (stage T1 and T2), without contamination of results from patients with stage T3 or higher disease, or without contamination of results from patients also treated with ADTs. How these contaminations would affect the “true” treatment effect estimate of radiation alone in only T1-T2 disease is unpredictable.

## Conclusion

Definitive benefits of radiation treatments compared to no treatment or no initial treatment for localized prostate cancer could not be determined because available data were insufficient. Data on comparative effectiveness between different forms of radiation treatments ES-7 (BT, EBRT, SBRT) are also inconclusive whether one form of radiation therapy is superior to another form in terms of overall or disease-specific survival. Studies suggest that higher EBRT dose results in increased rates of long-term biochemical control than lower EBRT dose. EBRT administered as a standard fractionation or moderate hypofractionation does not appear to differ with respect to biochemical control and late genitourinary and gastrointestinal toxicities. Available data suggest that BT might be associated with an increase in genitourinary toxicity compared with EBRT. BT appears to be largely comparable to EBRT in the rates of gastrointestinal toxicity. However, more and better quality studies are needed to either confirm or refute these suggested findings.