# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Patrick A. Kupelian, MD
  Oncologist
  MD Anderson Cancer Center Orlando
  Orlando, FL
- Colleen A. Lawton, MD, FACR, FASTRO
  Professor of Radiation Oncology
  Medical College of Wisconsin
  Milwaukee, WI
- W. Robert Lee, MD, Med, MS
  Radiation Oncologist
  Duke University Medical Center
  Durham , NC