# Discussion

In this technology assessment, we attempted to provide complete and comprehensive reviews of 19 different drug/diseases indications. At the time of their selection, these indications were all off-label. Over the time course of doing this project, the literature evolved quickly (e.g., the number of potentially relevant articles related to alemtuzumab published in a calendar year increased from 290 to 447 from 2006 to 2009) and the FDA approved several indications (e.g., all five of the indications for imatinib were approved over that period). For some indications there was both biological plausibility of the drug/disease combination as well as relatively compelling evidence to support the prescription of that particular drug in that particular disease (e.g., alemtuzumab in cutaneous T cell lymphoma [CTCL]), and in other indications evidence was scant or not at all supportive (e.g., bevacizumab in pancreatic cancer).

This technology assessment constituted, in effect, a series of 19 systematic reviews of the medical literature on off-label indications of selected antineoplastic drugs. In terms of sheer labor effort, the scope of this undertaking was vast. A first and important observation is, therefore, recognition of the quantity of work expected of the compendia which are charged with continuously performing and updating systematic reviews on the comprehensive list of FDA-approved drugs and biologics. Moreover, this study confirmed the pervasive sense among clinicians that the drug landscape in oncology is frequently changing, not only as new indications arise but also as public support and interest shift to focus on specific drugs (e.g., gefitinib fell out of favor over the course of this review).

In listing off-label indications, the compendia function as a stepping stone between (1) drug development and research that produces substantial supporting evidence, and (2) FDA approval.

For many of the indications included in this technology assessment, FDA listing was in progress. Here, the drug’s accessibility, via the mechanism of compendia off-label listing, jibes with this intended role of the compendia. We found that the volume of identified data was variable even for those agents that secured FDA approval, although those approved were primarily those with the more robust datasets identified in this review (e.g., the large number of studies for imatinib for acute lymphoblastic leukemia (ALL), and Phase III studies of bevacizumab for renal cell carcinoma). From our reviews, we could discern which drugs should not be accessible for the studied indication, and in general, their listing in the compendia was rescinded (e.g., bevacizumab for pancreatic cancer). The extent of review varied depending on expected usage and cost; expensive drugs likely to be used in common cancers (e.g., bevacizumab) tended to undergo full FDA review, whereas uncommon cancers did not.

Each discrete systematic review yielded interesting information on the off-label use(s) of a specific targeted therapy. However, the quality of studies varied tremendously, and the low quality of many published studies made it difficult to draw conclusions regarding the agent’s effectiveness or safety. Study quality varied both across and within drugs. Because of the paucity of high-quality evidence, the data available – though voluminous – may have little meaning or value for informing clinical practice. Similarly, our horizon scan yielded little useful evidence; review of this level of evidence may serve better as an early warning system, alerting clinicians to potential adverse events (e.g., CMV in alemtuzumab) than as a viable source of data on efficacy.

The indication of alemtuzumab for Non-Hodgkin Lymphoma (NHL) illustrates many of the issues encountered in a systematic review of the literature in the rapidly evolving field of targeted therapies. Clinical indication for use of alemtuzumab varied; specifically, we found the agent used at diverse stages of disease presentation. Four of the 11 published reports included alemtuzumab as a part of a stem cell transplant conditioning regimen, to reduce toxicity from donor lymphocyte infusion, or in conjunction with some other aspect of transplant therapy. Similarly, transplant was frequently the indication in abstracts and the horizon scan. In the remainder of studies, participants generally had relapsed or refractory NHL, or minimal residual disease after other standard therapies. Two abstracts presented the choice of alemtuzumab as first-line therapy in NHL; both involved patients with peripheral T cell lymphoma as their NHL subtype. In this wide variety of contexts, it is difficult – though necessary for the practicing clinician – to try to interpret efficacy outcomes and tolerability from the available evidence. In this drug/disease combination, reported response rates varied tremendously, from 4 percent to 80 percent. This variation could be due to the fact that many studies were not limited to a single disease or a single drug regimen; in studying alemtuzumab for NHL, as with other drug/disease combinations, patients with a variety of diseases were included in clinical trials.

The quantity, as well as quality, of data varied widely across the included indications. Practical considerations may account for some of this disparity in quality. Targeted therapies treat diseases that are frequently rare (e.g., alemtuzumab for T-cell prolymphocytic leukemia or imatinib for dermatofibrosarcoma protuberans [DFSP]); hence it is difficult to get many cases at one institution. Clinical trials are costly; hence it is impractical to expect cooperative clinical trials or industry-funded research of every permutation. In certain drug/disease combinations, (e.g., bevacizumab for epithelial ovarian cancer [EOC]), the data are severely limited. A published case series and case reports suggest that bevacizumab may contribute to clinical response in EOC, including reduction in CA125 levels. However, these studies were not designed to directly evaluate the efficacy of bevacizumab, and there is inherent bias in relying on case reports or retrospective case series to assess either efficacy or safety of interventions, especially those typically used in combination with other treatments. A larger quantity of data supported more mature drugs (e.g., imatinib). Given the complexities of completing clinical trials, and the small number of patients available at any single institution, the level of data for some drug/disease combinations was remarkable – and likely reflective of public enthusiasm for those drugs.

In some diseases, despite limited, lower quality, and/or ambiguous data, the use of an off-label indication may be a reasonable clinical decision. For example, given the rarity of dermatofibrosarcoma protuberans (DFSP) tumors, the substantial mortality risk for those tumors that progress into a sarcoma or metastasize, the lack of other systemic therapeutic interventions for DFSP, and the presence of the PDGF receptor as a target in DFSP, treatment with imatinib in DFSP is a sensible strategy even in the setting of few published reports, incomplete exploration in clinical trials, or data coming only from uncontrolled Phase II trials. Here, in a very immediate sense, the clinician’s judgment of best treatment choice for an individual patient must take into account whatever evidence is available, and base the decision on that data, albeit limited. Likewise, in certain diseases with long survival estimates, the short time period of drug development makes calculation of median survival impossible (e.g., rituximab for nodular lymphocyte-predominant Hodgkin disease) and clinicians must evaluate the evidence in the absence of survival data. The balance of adverse effects versus potential clinical benefit presses another clinical judgment on oncologists; for example, despite risk of adverse events, targeted therapies may be a good choice for heavily pre-treated NHL patients who can tolerate the adverse event profile and for whom there are no other established options (e.g., NHL patients with good performance status may benefit from alemtuzumab or bortezumab).

In interpreting some studies, there may be a temptation to assume that efficacy is implied by the presence of a logical target (e.g., bevacizumab for ovarian or pancreatic cancer). In some drug/disease combinations (e.g., imatinib for ALL), a target was always present. Sometimes the target was defined as an eligibility criterion, and sometimes not; for example the alemtuzumab target, CD52, was not a prerequisite for study entry in trials of alemtuzumab for NHL and it was not clearly linked to outcomes. However, in nearly all of the NHL settings where alemtuzumab was used, the presence of CD52 could be confidently assumed; only one study required CD52 positivity.

In this technology assessment, the array of data presented in randomized controlled trials, controlled clinical trials, case series, case reports, abstracts, review articles, and other reports raised the issue of what constitutes “evidence.” Disagreements are likely to surround this question, making the process of evidence review susceptible to differences of opinion and subjectivity. Much of the evidence retrieved through this series of systematic reviews would not, generally, be considered “good science;” the identified publications presented results of Phase II trials, were inadequately controlled, had potential conflicts of interest due to funding scenarios, involved double-counting across studies, or did not conform to good clinical practice. Sometimes the remarkably low quality of the reporting obscured any ability to determine the strength of the evidence. The pace of research, combined with clinical urgency, may at times threaten the integrity of the science underlying clinical decisions.

Abstracts, a harbinger of emerging trials, become available at ASCO and could inform decisions supporting the use of an agent before the fully published reports become available (e.g., bevacizumab for renal cell carcinoma). Sometimes referred to as the “June 5 effect,” oncologists start applying new data presented in abstract form at the ASCO conference that takes place at the beginning of June, often with a resulting uptick in relevant drug utilization. Because of the nature of evidence available to compendia reviewers as well as clinicians, the use of targeted therapies may not be based on sound or robust scientific evidence.

The timeliness of evidence review and the pace of research are particularly acute issues in oncology. Many cancers are potentially life-limiting diseases, for which there are few if any effective treatment options. Oncologists and patients find themselves in a situation characterized by urgency, fear, and a desperate desire to take action in hopes of a response. Cancer care providers, therefore, may approach the literature from a different perspective than do primary care providers or those in other disciplines where outcomes are not as dire. In the cancer setting, the definition of what constitutes “evidence” may thus be substantially looser than in other disciplines, and providers reviewing the evidence may be more inclined to entertain data derived from lower-quality studies or the “gray” literature. It has been estimated that less than half of all medical care in the United States is based on or supported by [underlined: adequate] evidence about its effectiveness.8 This may be particularly true in cancer (especially as we question the adequacy of the evidence identified in this review).

The exercise of performing 19 systematic reviews of off-label indications in oncology pointed to clear challenges in the current methods of evidence review; these challenges are likely heightened in areas of medicine where research is advancing rapidly and scientific productivity is high. A different model of evidence generation and evaluation is warranted – but is it possible? What would such a model look like? Much discussion is currently underway in national forums to answer these questions.

Developing consensus holds that the new system must be designed for rapid learning and expedient translation of research results into clinical practice improvements, and must include evaluation of the comparative effectiveness of available treatments in real-world clinical populations. As yet, there is no articulated consensus on the role of comparative effectiveness research [CER] in evaluation of cancer treatments, but national discussion is striving to define the parameters of, and the appropriate context for, CER. In the words of an expert committee convened by the Friends of Cancer Research and comprising leading academic scientists, clinicians, and advocates in the field of cancer, “To ensure that evidence-based information on the effectiveness and comparative effectiveness of medical care keeps pace with the newest diagnostic and therapeutic interventions, the nation’s approach to the performance of CER must be structured to ensure continuous learning and the rapid translation of the best available evidence into clinical practice. Ultimately, we need to move closer to the development of a sustainable, ‘learning’ U.S. health care system that develops research insights as a natural byproduct of the care process and gets the right care to people when they need it and then captures the results for improvement.”9 Two clear foci of this technology assessment that highlight the need for comparative effectiveness research within a learning healthcare system model are: (1) the nature of adverse event data, where the patterns for new/emerging adverse events which we identified were largely case reports; until we can describe a pattern of such events, e.g., through data collected routinely in a rapid learning healthcare model, sporadic reports of adverse events have little clinical utility; and (2) the lack of comparative effectiveness data, where the volume of Phase II studies of targeted therapies serves only to suggest potential benefit but not to describe how each new therapy may compare to other available treatments in terms of relative efficacy or tolerability. It remains unclear, however, whether CER is more appropriate than other types of clinical trial for establishing the efficacy and role of targeted therapies in treating specific cancers, and thus whether and how CER should be integrated into drug discovery trials.

While it is beyond the scope of this technology assessment to discuss rapid learning healthcare or comparative effectiveness research, these topics represent a logical next area of exploration in the effort to understand and improve upon the state of the evidence available to support medical care.

The principal limitation of this technology assessment was the variability in quality and quantity of data which made the drawing of conclusions regarding either the efficacy or the safety of the included drugs and respective indications both difficult, if possible, and inconclusive. At times, the volume of poorly done work was remarkable; for example, with rituxumab for chronic lymphocytic leukemia, despite abstracting 81 reports, we were unable to draw conclusions. Second, with respect to drug efficacy, our review may be skewed by publication bias; the publication of negative results typically lags behind publication of positive results, hence this review may disproportionately weight studies reporting positive findings. Even if negative results were published, our search may not have picked them up if they preceded the less than ten-year window of literature which we examined. A third limitation is that our literature review does not include published reports indexed in MEDLINE® after September 14, 2007.