# Results

## Velocity of Evolution of the Literature

An important outcome of this technology assessment is its description of the state of the evidence in a single, quickly evolving, field of biomedical research. The body of literature surrounding targeted therapies is growing at a rapid rate (Table 3). Significant difficulty was encountered in the conduct of this study due to the continuous change in the available evidence; akin to drawing a line in the sand, we placed time boundaries for study inclusion – a necessity in order to proceed with any search strategy. As new information became available, however, we felt compelled to redraw the line in the interests of performing the most complete systematic review possible. This approach is largely infeasible and delayed completion of the study. In a larger sense, the “moving target” nature of evidence calls into question the feasibility of a time-bounded, static, evidence review process based on systematic review, in an environment where the evidence pool is continuously expanding.

Illustrating this challenge, Table 3 presents the number of identified publications available by December of the search year. The searches included only those drug/disease combinations planned for this technology assessment, using the search strategy outline above; total number of papers are presented by agent (summing across diseases, if more than one drug/disease combination was evaluated for that particular agent).

Table 3 Number of identified publications reporting on select off-label indications of each targeted therapy

Targeted therapy | 2005 | 2006 | 2007 | 2008 | 2009^*^
Alemtuzumab (Campath®) | 238 | 290 | 343 | 395 | 447
Bevacizumab (Avastin®) | 82 | 148 | 257 | 420 | 558
Bortezomib (Velcade®) | 32 | 52 | 82 | 119 | 137
Cetuximab (Erbitux®) | 22 | 28 | 38 | 58 | 64
Erlotinib (Tarceva®) | 15 | 31 | 49 | 68 | 78
Gefitinib (Iressa®) | 58 | 87 | 110 | 137 | 149
Imatinib (Gleevec®) | 173 | 228 | 306 | 383 | 451
Rituximab (Rituxan®) | 286 | 352 | 418 | 481 | 565

* 2009 figures are extrapolated using 6-month figures, as follows: 2009 estimate = 2008 estimate + [(total through June 2009) – (total through 2008)] × 2.

## Systematic Literature Review for Drug/Disease Combinations

The Appendix summarizes the literature identified through the final search date of September 14, 2007. Each section covering a specific drug/disease combination follows the same structure, namely:

» Background
  - Overview of drug
  - Overview of disease
  - Rationale for use of drug in disease
» Methods
» Results
  - Studies identified
  - Efficacy
  - Survival
  - Adverse Events
  - Horizon Scan
» Discussion (Summary of findings)
» Supporting tables
  - Appendix Table 1 – Full published reports of studies for drug/disease combination
    - Study
    - Study design
    - Patients
    - Tumor response
    - Survival
    - Other including quality assessment
  - Appendix Table 2 – ASH & ASCO abstracts (2006/2007) presenting studies for drug/disease combination
    - Study
    - Study design
    - Patients
    - Tumor response
    - Survival
    - Other including adverse events and tolerability
  - Appendix Table 3 – Horizon scan studies for drug/disease combination
    - Study
    - Study design
    - Drug dose per day
    - Sample size
    - Comments
  - Appendix Table 4 – Adverse events (grade 3 & 4 only) from full published reports of studies for drug/disease combination

The summary of findings by indication presented here (Table 4) recapitulates the discussion section of each drug/disease section.

Table 4 Indications and summary of the systematic evidence review (last search date September 14, 2007)

Targeted therapy | Off-label indication(s) | Summary discussion
Alemtuzumab (Campath®) | Cutaneous T-cell lymphoma | There are emerging data for the role of alemtuzumab in the treatment of patients with progressive CTCL. Historically, single and combination chemotherapies for advanced disease (e.g., gemcitabine; methotrexate; cyclophosphamide, hydroxydaunomycin, Oncovin®, and prednisone [CHOP]) have had variable response rates, high risk of neutropenic infections, and short median survivals. In Phase II reports, alemtuzumab compares favorably to these existing treatment options. This review identified four published Phase II reports suggesting some efficacy, with PR rates ranging as high as 79% and median survival reaching 35 months (though a median survival rate as low as four months was also reported). The ASH abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. Toxicities were predominantly hematological and as expected. Over time, our understanding of the CMV risk with alemtuzumab is improving; this clarity stands out as the main emerging information in the most recently published abstracts.
Alemtuzumab (Campath®) | Non-Hodgkin lymphoma | These are some of the most mature and disparate data reflecting the efficacy of alemtuzumab for the treatment of patients with progressive lymphoma, most notably because this dataset encompasses the mix of studies from both before and after the FDA-approval of alemtuzumab for one NHL sub-type, CLL. Further, these data reflect the use of alemtuzumab in a variety of settings; e.g., as monotherapy for relapsed/refractory NHL and as a conditioning regimen for stem cell transplantation. As a result, the efficacy results are divergent and difficult to interpret. Key messages of the published dataset are the following: 1) alemtuzumab may have a place in the therapy of general NHL for heavily pre-treated patients who can tolerate the adverse event profile (e.g., patients with good performance status) and for whom there are no other established options; 2) alemtuzumab may have a significant role in the preparatory management for stem cell transplantation; 3) new NHL sub-classifications particularly responsive to alemtuzumab, such as monotherapy for newly diagnosed peripheral T-cell lymphoma, are likely to emerge; and, 4) adverse events for alemtuzumab are as expected (i.e., predominantly hematological), with data supporting the importance of CMV reactivation as a major concern with alemtuzumab. Demonstration of the alemtuzumab target, CD52, was not a requisite for study entry and not clearly linked to outcomes, although in nearly all of the NHL settings where alemtuzumab was used, the presence of CD52 could be confidently assumed.
Alemtuzumab (Campath®) | T-cell prolymphocytic leukemia | There are emerging data for the role of alemtuzumab in the treatment of patients with T-PLL. Historically, single-agent pentostatin therapy has resulted in reasonable response rates, though response duration is often short and disease progression and death occur relatively quickly. Second-line therapies remain unsatisfactory for this disease in most cases. In Phase II reports, alemtuzumab appears to be active in the second-line therapy of this disease, though disease-free and overall survival outcomes are were not adequately reported. A role for alemtuzumab as front-line therapy for T-PLL was not evaluated in the trials identified during this review. This review identified four published Phase II reports suggesting significant efficacy, with CR rates as high as 60% and median overall survival reaching 19 months in one report. The ASH/ASCO abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. As expected, toxicities were predominantly hematological and infectious. Over time, our understanding of the risk of CMV and other opportunistic infections with alemtuzumab is improving, resulting in appropriate prophylactic strategies and early detection and treatment of infectious complications.
Bevacizumab (Avastin®) | Breast cancer^*^ | Because multiple treatment regimens are available to patients with metastatic breast cancer, and patients with no visceral involvement will sometimes live for years with their disease, demonstration of survival benefit from the addition of a VEGF inhibitor to the treatment regimen will be difficult. This review identified a single clinical trial that assessed the marginal benefits and harms associated with bevacizumab as adjunctive therapy in the treatment of breast cancer. That trial compared capecitabine alone to capecitabine with bevacizumab among patients with previously treated metastatic breast cancer. Bevacizumab contributed to improved response rates but not progression-free survival. The existing literature suggests that bevacizumab is relatively well tolerated at doses of 10 to 15 mg/kg every two to three weeks. Leukopenia and hypertension were the two most common serious adverse events. The ASCO 2007 abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. Additional research is needed to determine whether the addition of a VEGF antibody, which has clearly been shown to be effective in the treatment of some cancers, and for which there is biological plausibility for the treatment of breast cancer, adds significantly to the current treatment options for metastatic breast cancer in terms of survival benefit. The FDA approved the use of bevacizumab for breast cancer in 2008 based upon emerging data, some of which were not available at the time of the most recent literature search presented in this report.
Bevacizumab (Avastin®) | Epithelial ovarian cancer | There are compelling reasons to evaluate the use of monoclonal antibodies to VEGF in the treatment of epithelial ovarian cancer, especially in light of ovarian cancer’s high mortality rate and the proven efficacy of this class of targeted therapies in the treatment of colon, rectal, non-small cell lung, and breast cancers, and glioma.. However, to date there are limited data that support the use of bevacizumab in the treatment of epithelial ovarian cancer. The published case series and case reports suggest that bevacizumab may contribute to clinical response, including reduction in CA125 levels. These studies were not designed to directly evaluate the efficacy of bevacizumab, however, and there is inherent bias in relying on case reports or retrospective case series to assess either efficacy or safety of interventions, especially those typically used in combination with other treatments. The ASCO abstract and horizon scan articles did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. There were insufficient data identified in this review to comment on toxicities potentially associated with bevacizumab in the treatment of ovarian cancer.
Bevacizumab (Avastin®) | Pancreatic adenocarcinoma | The findings from the Phase II studies suggest that bevacizumab does little to improve clinical outcomes in the treatment of pancreatic adenocarcinoma. Complete responses ranged from 0 to 1% in these studies. The single Phase III trial, which enrolled 602 patients and compared gemcitabine plus bevacizumab 10 mg/kg to gemcitabine plus placebo, did not demonstrate a survival benefit associated with bevacizumab. These findings are consistent with recently published expert opinion that there is no consensus about second-line therapy after pancreatic cancer progression after gemcitabine failure.
Bevacizumab (Avastin®) | Renal cancer^*^ | Given the upregulation of VEGF associated with the mutated version of the von Hippel–Lindau tumor suppressor gene in the majority of renal cell cancers, drugs that target the inhibition of angiogenesis are logical therapeutic agents. The findings from this review support the use of bevacizumab in the treatment of renal cell cancer. The three fully published trials as well as the published abstracts demonstrated that bevacizumab appears to be both well tolerated and efficacious. The Phase III clinical trial published in abstract form demonstrated a 30.6% complete response associated with bevacizumab, compared to 12.4% associated with placebo when administered along with interferon therapy. Hypertension and proteinuria are among the more common adverse events associated with bevacizumab therapy.
Bortezomib (Velcade®) | Non-Hodgkin lymphoma | Although preclinical studies suggest a potential role for proteasome inhibitors in the treatment of hematologic malignancies, the studies identified in this review do not provide sufficient evidence to recommend the use of bortezomib in the treatment of NHL and related diseases. The quality of the uncontrolled Phase II studies was generally poor, and there were no randomized controlled trials that compared bortezomib to alternative therapies. Clinical response was highly variable, with CR and PR rates ranging from 0 to 90%. The patient populations represented in the studies were heterogeneous, as were the history of prior treatments and the other interventions used concurrently with bortezomib. Dosing of bortezomib ranged from 1.3 to 1.8 mg/m^2^ at intervals ranging from 3 to 10 days. The ASH 2006, ASH 2007, and ASCO 2007 abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. The horizon scan revealed reports of cardiovascular toxicities, including arrhythmias, as well as a potentially higher incidence of varicella herpes zoster among patients being treated with bortezomib. Further research is needed to determine what role, if any, bortezomib should have in the treatment of NHL, with the exception of mantle cell lymphoma.
Cetuximab (Erbitux®) | Pancreatic adenocarcinoma | Results from the clinical trials published as abstracts demonstate that the use of cetuximab as an adjunct in the treatment of pancreatic adenocarcinoma is associated with an increase in partial response from 8% to 16%. Only a single subject who received cetuximab had a complete response. Further research is needed to evaluate the efficacy and safety of cetuximab for patients with this cancer.
Erlotinib (Tarceva®) | Head and neck cancer | The overexpression of EGFR in 80% to 100% of HNSCC makes erlotinib a logical targeted therapy for HNSCC. The two full reports and the four abstracts in this review provide emerging evidence for the role of erlotinib in the treatment of patients with HNSCC. Historically, single and combination chemotherapies for advanced disease have had low response rates and short median survivals. In Phase II reports, erlotinib compares favorably to existing treatment options. This review identified two published Phase II reports suggesting some efficacy, with partial response and stable disease rates of 19% and 49%, respectively, in one of the studies. Complete response rates were highly variable across the six studies, ranging from 0 to 84%. There was a relatively low rate of toxicities reported in the two full reports, with dermatitis being the most commonly reported adverse event. The reports identified in this review did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates.
Gefitinib (Iressa®) | Head and neck cancer | The paucity of published reports and the heterogeneity of the patient populations and the dosages studied preclude drawing conclusions at this time regarding the role of gefitinib in the treatment of HNSCC. Data available do not support its off-label use. Access to this drug has been severely restricted in the United States following the FDA approved labeling change in June 2005, such that gefitinib is seldom used either on-label for lung cancer or off-label for HNSCC. Interest in further clinical trials of this agent has also waned in the United States due to issues of access.
Imatinib (Gleevec®) | Acute lymphoblastic leukemia^*^ | The constitutively activated tyrosine kinase bcr-abl, a product of the Philadelphia chromosome, is present in 20% to 30% of ALL cases. Because imatinib specifically targets cells with the Philadelphia chromosome, it is potentially useful as adjuvant therapy for patients with Ph+ ALL. This review identified two randomized clinical trials and 22 uncontrolled trials involving 1,430 patients with ALL, the vast majority of whom were previously untreated and were Philadelphia chromosome positive. Neither of the two randomized clinical trials identified in this review evaluated the efficacy of imatinib for ongoing treatment. One randomized trial demonstrated improved median survival when imatinib was added to ongoing to the induction regimen; all patients received imatinib during the ongoing treatment period in this study (the other randomized study did not have response or survival data available yet at the time of this review). The evidence from the Phase II trials suggests that this targeted therapy may be effective either as monotherapy or as combination therapy in the treatment of ALL, across the treatment settings studied, with CR rates in some studies reaching 100%. These favorable results must be considered in the context of the expected treatment success rates of existing therapies, which are generally high in the initial treatment of Ph+ ALL, maintained across treatment plans in children, and lead to treatment failure in adults; it follows that imatinib is usually used in adults with Ph+ ALL. The ASH/American Society of Clinical Oncology (ASCO) abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. These reports did, however, suggest that imatinib may be associated with a variety of different adverse events, including acute tumor lysis syndrome, cardiotoxicity, or pleural effusion.
Imatinib (Gleevec®) | Chronic eosinophilic leukemia^*^ | Each of the nine case reports or series considered in the horizon scan reported favorable responses to imatinib without significant toxicity in the treatment of chronic eosinophilic leukemia. The RT-PCR analysis suggests that there is sensitivity of the PDGFR alpha fusion to imatinib.
Imatinib (Gleevec®) | Dermatofibrosarcoma protuberans^*^ | The vast majority of DFSP tumors have a chromosomal translocation that fuses the collagen gene with the PDGF gene, the result of which is the production of a self-stimulatory growth signal, rapid cell division, and tumor formation. This process involves the constitutive activation of the PDGF receptor, which provides a rationale for targeted inhibition of the PDGF receptor as a treatment strategy for patients with unresectable locally advanced or metastatic DFSP. This review identified two Phase II reports involving 35 patients with DFSP treated with imatinib as monotherapy. Neutropenia and maculopapular rash were the only Grade 3 adverse events reported. Fifty percent of patients in the full report demonstrated a PR and 36% of patients in the trial published as an abstract demonstrated a clinical response. In these Phase II reports, imatinib compares favorably to existing treatment options. The ASCO 2007 abstract and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. Given the rarity of DFSP tumors, the substantial mortality risk for those that transform into a sarcoma or metastasize, the lack of other systemic therapeutic interventions for DFSP, and the presence of the PDGF receptor as a target in DFSP, treatment with imatinib in DFSP is a sensible strategy even in the setting of few published reports and incomplete exploration in clinical trials identified in this review.
Imatinib (Gleevec®) | Myelodysplastic syndrome^*^ | Recent research suggests that some MDS patients express the PDGF receptor oncogene, and that PDGF has been implicated in the pathogenesis of various myeloproliferative disorders. This offers a rationale for targeted inhibition of the c-kit and PDGF receptor oncogenes as an MDS treatment strategy. This rationale, combined with the fact that MDS is often refractory to existing treatments, suggests that imatinib may be a potentially important targeted therapy for MDS. The published data described in this review suggest that imatinib is well tolerated in this patient population, with the only commonly occurring adverse event being neutropenic fever (21%). The two studies involving a total of fewer than 50 patients provide insufficient data to support firm conclusions, but their findings suggest that imatinib is not effective in the treatment of MDS. Complete response was achieved in a single patient, and only one patient achieved a partial response.
Imatinib (Gleevec®) | Systemic mastocytosis^*^ | Over the past few years, clinical research initiatives aimed at developing more tolerable and effective therapies for SM have investigated treatments, including imatinib, that specifically target the constitutive kinase activity of the mutated c-kit proto-oncogene and the FIP1L1-PDGFRα fusion gene. This review identified three Phase II reports involving 29 patients with SM treated with imatinib as monotherapy or in combination with prednisone. The results suggest that imatinib is well tolerated among patients with SM, with the only commonly occurring Grade 3/4 adverse event (7%) being toxicoderma. These three reports provide insufficient data to support firm conclusions, but their findings suggest some efficacy of imatinib in the treatment of SM, with PR rates ranging between 30% and 100%. The ASH 2006 abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. Given the rarity of SM (and lack of patients for clinical trials), the need for systemic therapeutic interventions among some patients with severe and/or highly symptomatic disease, and the presence of a target for imatinib in this disease, treatment with imatinib in SM is a sensible strategy even in the setting of few published data and the incomplete exploration in clinical trials identified in this review.
Rituximab (Rituxan®) | Chronic lymphocytic leukemia | As an anti-CD20 immunoglobulin, rituximab is theoretically well suited to treating CD20-positive CLL. Nearly all of the reports identified in this review included only patients with CLL known to have CD20-positive status. These reports provide relatively compelling evidence in support of the role of rituximab in the treatment of CLL. The quality of the studies was generally poor, and there is great variability in the clinical response rates, but in the aggregate the reports suggest some efficacy. CR and PR rates ranged from 0 to 70% and 15% to 67%, respectively, among the 16 fully published studies, and no clear pattern of the type or nature of adverse events possibly associated with rituximab use among patients with CLL was evident. Comparative effectiveness trials are needed to better determine the appropriate role of rituximab in the treatment of CLL.
Rituximab (Rituxan®) | Nodular lymphocyte-predominant Hodgkin disease | Because rituximab is an anti-CD20 immunoglobulin that antagonizes the high-density CD20 surface antigens characteristic of the malignant cell population of NLPHD patients, it has emerged as a promising treatment option since its first off-label use in 1999 for a patient with difficult refractory NLPHD. Subsequent case reports and Phase II studies identified in this review provide further evidence that rituximab appears to be both effective in the short term and well tolerated, but that the duration of response may be limited. The observed CR and PR rates of 45% to 69% and 28% to 54%, respectively, compare favorably to existing treatment options, as do the estimated 10- and 20-year overall survival rates of 97% and 85% reported in a published abstract. The ASH 2006 and 2007 abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates. Only one out of 14 patients (7%) experienced a Grade 3/4 adverse event in the single study that reported adverse events.
Rituximab (Rituxan®) | Waldenstrom’s macroglobulinemia | Rituximab, an anti-CD20 immunoglobulin that targets the CD20 surface antigens that are expressed on malignant lymphocytes in WM, was used as an off-label treatment for WM from the late 1990s until its recent approval by the FDA. This review identified 13 published Phase II reports suggesting some efficacy, with one reported CR rate reaching 18% and PR rates ranging as high as 90%. Historically, single and combination chemotherapies for advanced disease have had variable response rates and short median survivals. In Phase II reports, rituximab was generally well-tolerated, and it compares favorably to these existing treatment options. The ASH 2006, ASH 2007, and ASCO 2007 abstracts and horizon scan did not suggest any major modifications in the dosing schedule, planned combinations with other drugs, or anticipated response rates.

* Indications that were approved by the FDA at some point during the completion of this technology assessment.