# Methods

## Selection Criteria

### Selection of Drugs

Medications currently being used for off-label indications in oncology were included in the systematic review if they met the following inclusion criteria:

- Targeted agent;
- FDA-approved;
- Marketed in January 2007 or before; and,
- Having compendia-listed indications other than the FDA-approved indication, in one of the following four compendia as of December 2006: AHFS-DI (2006 version), NCCN (online version), USP-DI (2006 version), and Clinical Pharmacology (online version).

### Selection of Studies

Each citation identified from the search strategies was evaluated by the investigators according to the following selection criteria.

Studies were included in the evidence tables if they met all of the following inclusion criteria:

- Conducted in humans;
- Investigated use of the candidate drug for the off-label indication;
- Addressed one of the off-label indications listed in Table 1 for included drugs;
- Reported at least the following outcomes for efficacy: survival, disease-free survival, tumor response, quality of life, or adverse effects.

All study designs – case reports, retrospective case series, clinical trials (Phase I, Phase II, Phase III, Phase IV), and large database (outcomes) studies – were included. Any type of tumor response criteria was considered to meet the eligibility criterion regarding efficacy outcome.

Studies were not included if they met any of the following exclusion criteria:

- Described only predictors of response;
- Was a pharmacokinetic study (i.e., a study in which outcomes are drug levels);
- Was conducted in a non-human setting (i.e., animal model or in vitro).

Our previous review of the quality of the compendia found that the compendia used information from abstracts, review articles, and other types of reports, in addition to randomized controlled trials, to support their listed recommendations. Hence, to ensure that our dataset was complete, we also included this level of information in our review. Studies that did not meet the eligibility criteria for inclusion in the evidence tables, or that were presented in abstract form only (i.e., without a companion published manuscript), were summarized in horizon scan and abstract tables only.

## Search Strategy

A systematic MEDLINE® search employed the following algorithm:

1. alemtuzumab.mp. (1034)
2. campath.mp. (669)
3. exp lymphoma, t-cell, cutaneous/ (6371)
4. exp lymphoma, non-hodgkin/ (68316)
5. leukemia, prolymphocytic/ (391)
6. leukemia, t-cell, chronic/ (185)
7. leukemia, lymphocytic, chronic/ (8687)
8. (1 or 2) and (or/3–7) (421)
9. (bortezomib or velcade).mp. (1733)
10. exp lymphoma, non-hodgkin/ (68316)
11. 9 and 10 (128)
12. (bevacizumab or avastin).mp. (2720)
13. exp Breast Neoplasms/ (165832)
14. ovarian neoplasms/ (49018)
15. exp pancreatic neoplasms/ (42132)
16. exp kidney neoplasms/ (46624)
17. 12 and (or/13–16) (489)
18. (cetuximab or erbitux).mp. (1497)
19. exp pancreatic neoplasms/ (42132)
20. 18 and 19 (61)
21. (erlotinib or tarceva).mp. (1300)
22. exp "Head and Neck Neoplasms"/ (195248)
23. 21 and 22 (73)
24. (gefitinib or iressa).mp. (2337)
25. exp "Head and Neck Neoplasms"/ (195248)
26. 24 and 25 (143)
27. (imatinib or gleevec).mp. (5493)
28. exp leukemia, lymphocytic, acute/ or exp leukemia, t-cell, acute/ (16285)
29. chronic eosinophilic leukemia.mp. (115)
30. dermatofibrosarcoma/ or dermatofibrosarcoma protuberans.mp. (1065)
31. exp Myelodysplastic Syndromes/ (12465)
32. exp mastocytosis, systemic/ (383)
33. 27 and (or/28–32) (417)
34. (rituximab or rituxan).mp. (5132)
35. exp leukemia, lymphocytic, chronic/ (8687)
36. hodgkin disease/ or "nodular lymphocyte predominant hodgkin$ disease".mp. (28136)
37. waldenstrom macroglobulinemia/ (4062)
38. (waldenstr$ adj1 macroglobulinemia).mp. (4395)
39. 39 34 and (or/35–38) (523)

Because we were frequently notified of new reports that might have been missed if the search were not updated, the above search strategy was conducted at multiple timepoints during the conduct of this technology assessment. With respect to collecting abstracts and published reports for review in the literature synthesis, the search was last run on September 14, 2007.

Because the literature was evolving rapidly, and because the compendia frequently referenced unpublished conference abstracts from key international meetings such as the American Society of Clinical Oncology (ASCO) and American Society of Hematology (ASH) annual conferences, we supplemented the literature search with searches of conference abstracts for 2006 and 2007 (ASH and ASCO). We did not repeat this in 2008 or 2009, because the conference abstracts were minimally instructive to our overall understanding of the literature. In order to search the abstracts, we used the professional organizations’ online databases, searching by drug name cross-matched with disease and using the same search terms as outlined above.

## Data Abstraction

Data were abstracted from journal articles and abstracts directly into standardized data tables by four investigators independently. One data table was completed for each drug/disease combination (i.e., a targeted therapy and a specific off-label use of that targeted therapy). Each data table was over-read by an investigator other than the one who originally abstracted the data for that drug/disease combination.

The following data were abstracted from included studies: study design, phase, selection/randomization, and eligibility criteria; number of patients, median age, previous treatment, stage of disease, drug dose per day, and outcomes sought; tumor response (number with tumor response assessed, complete response, partial response, stable disease, progressive disease); survival (overall, median, disease-free); adverse events and tolerability; and quality assessment (see below). Data tables were created using Microsoft Excel (Microsoft, Inc.; Redmond, WA).

Please note the following additional details:

- Journal articles which reported results of Phase I dosing studies were considered as horizon scan reports rather than as full-text reports; hence these reports were not included in the primary data tables.
- For most drug/disease combinations reviewed, data populating the adverse events tables were abstracted from full reports only, and not from abstracts. Due to space constraints, abstracts do not typically include information on adverse events.

## Quality Assessment

The quality of included studies was assessed on the following quality elements: internal validity (e.g., randomization and allocation concealment; similarity of compared groups at baseline; specification of eligibility criteria; blinding of assessors, care providers, and patients) and external validity (e.g., description of the patient population, similarity to the target population of the report, use of highly selective criteria). We adopted as a framework the quality assessment criteria used in a 2003 British report on imatinib mesylate for unresectable and/or metastatic gastrointestinal stromal tumors (GIST).6 These criteria were, in turn, drawn from a 2001 methodological publication of the British National Health Service Centre for Reviews and Dissemination.7 The specific quality criteria we selected cover the range of study designs used in this report including experimental studies, cohort studies, case-control studies, and case series. Point scores were allocated by assigning one point for each quality category. There were a total of six possible categories. Quality ratings of “yes” to a quality criteria were assigned 1 point; no and unknown were both assigned 0 points. The last category, adequate description of subseries, was not applicable to all studies. Hence, the total possible quality points were 5 or 6 depending upon the applicability of the subseries category. High quality studies were those with ≥ 3/5 or 4/6 points. Abstract quality was not scored.

## Data Synthesis

In addition to data abstraction and quality analysis, a narrative description of study findings was prepared. Results are presented in Chapter 3, immediately below.