# Background

## Clinical Context

Traditional anticancer treatment has relied on cytotoxic chemotherapy as a primary intervention. Chemotherapy has proven effective for many cancer diagnoses because it is toxic to rapidly proliferating cells such as tumor cells. As a systemic treatment, however, it also affects normal cells in the surrounding or peripheral area, and can alter, impair, or destroy those cells. Rather than damaging only the tumor, it typically causes multiple undesirable side effects which impair the patient’s function, quality of life, and even survival.

Over the past 10 years, seeking to develop antineoplastic treatments with less associated toxicity, scientists and clinicians have tested a number of more specific agents termed “targeted therapies.” These agents are designed not to kill cells but, more precisely, to attack growth factors, cell surface receptors, and intracellular proteins that mediate a malignancy’s ability to proliferate, grow, or evade cell death. Examples of targeted therapies include small molecule inhibitors, monoclonal antibodies, and conjugated agents. Several of these agents have been successfully brought into routine clinical use.

Targeted therapies have been heralded as a promising new approach to cancer treatment; they have raised hopes and expectations of cure for previously intractable cancers, without the toxicity associated with traditional chemotherapy. They can be used as single agents, in combination with chemotherapy, or in combination with other targeted therapies. Their toxicity profile and scope of applicability differs from that of traditional chemotherapies. As new agents, with intensive research and development preceding their introduction into the market, they are currently very expensive.

Scientific enthusiasm surrounding targeted therapies has prompted a flurry of research activity focused on harnessing their potential. Consequently, the list of potential uses for targeted therapies has expanded, and continues to expand rapidly, beyond the original FDA-approved indications for these new drugs. The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Duke (Contract Number: HHSA 290-02-0025). This technology assessment has been conducted to evaluate the state of the evidence supporting the use of targeted therapies outside of their FDA-approved indications; it also evaluates the practicality of traditional systematic review approaches in rapidly evolving therapeutic areas such as targeted therapies for various cancers.

## Technology Assessed

The advent of targeted therapies has raised hopes of a new approach to cancer treatment – one that does not entail the deleterious collateral damage, adverse effects, or symptom side effects of traditional chemotherapy and radiation therapy. Targeted therapies that specifically damage or destroy cancer cells, while minimizing the effects on normal cells, currently include antibody therapies and small molecules, with gene therapies potentially an additional approach on the horizon.

### Types of Therapies Considered

Antibody therapies use targeted antibodies to bind to a specific protein, thereby blocking its activity. Other mechanisms may also factor into the success of antibody therapies in treating cancer. For example, the complement and immune systems can recognize antibodies, and may destroy the cells to which the antibodies are bound.

Monoclonal antibodies are classes of identical antibodies produced by a single type of immune cell, and that have an affinity for a specific antigen. Attaching to tumor cells, monoclonal antibodies mark the cell for attack by the immune system, block specific transmembrane receptors, or deliver chemotherapeutic or radioactive drugs. Bevacizumab, now the standard of care for treatment of metastatic colon cancer, is an example of a monoclonal antibody in widespread clinical use.

Conjugated agents, another antibody therapy, represent a class of targeted therapies in which an antibody or protein is linked to a toxin or radioisotope. The antibody or protein component brings the entire cytotoxic agent to the cancer cell of interest, hopefully without binding to normal cells. This approach is designed to provide the benefit of radiation or chemotherapy on a cell-specific basis. An example is tositumomab, where an anti-CD20 antibody is covalently bound to ^131^I, indicated for use in refractory follicular lymphoma. Since these drugs are rarely used off-label at present, they are not discussed further in this technology assessment.

Small molecule targeted therapies are drugs specially designed to bind certain receptors that inhibit signaling pathways for growth and proliferation within tumor cells. Small molecule inhibitors enter cells and disrupt protein functions and interactions. An example of a small molecule is imatinib, which has become standard of care for chronic myelogenous leukemia and gastrointestinal stromal tumors (GIST).

Many small molecules, including imatinib, inhibit the function of tyrosine kinases. Normally, the binding of various soluble factors outside normal tissue to cell surface receptors activates tyrosine kinases. These tyrosine kinases may either be a component of the receptor or an associated protein. When activated, they turn on a cascade of other proteins inside the cell, ultimately increasing the cells’ ability to grow and divide. One way in which cancer cells proliferate and become resistant to cell death is by increasing the number of cell surface receptors, thus amplifying pro-survival signals. Another mechanism is mutatation of the tyrosine kinases associated with these receptors, thereby resulting in constitutively active kinases, ultimately causing uncontrolled cell proliferation. In either situation, tyrosine kinase inhibitors locate and bind to specific proteins, thereby causing a desirable effect, such as inhibiting vascular endothelial growth.

Another category of small molecule inhibitor is the proteosome inhibitor. Cellular functions such as proliferation and cell death in normal cells are dependent on levels of various intracellular proteins. The levels of these proteins are controlled in part by degradation, a function performed by the proteosome. Treatment with a proteosome inhibitor blocks the degradation of proteins; in cancer cells, this can push the cell towards cell death.

Gene therapies deliver genetic material into an individual’s cells using a vector, usually a virus. The purpose of these treatments is to block expression of genes that promote tumor development, and/or to replace missing or defective tumor-suppressor genes. Such treatments may make tumor cells more susceptible to standard chemotherapy or radiotherapy. They may make normal tissues less susceptible to the damage induced by conventional treatments. Or, by eliminating specific abnormalities that triggered the normal cell to become neoplastic, they may remove the tumor cell’s ability to proliferate unchecked. Because gene therapy is, as yet, an experimental treatment that is not available outside of a clinical trial, gene therapies are not included in this technology assessment.

### Inclusion criteria for targeted therapies

This technology assessment evaluates the strength of the evidence for targeted therapies. To include a maximum number of agents being used for off-label indications in oncology, we included medications that were: (1) FDA-approved targeted agents; (2) marketed in January 2007 or before; and (3) with compendia-listed indications other than the FDA-approved indication as of December 2006.

Consistent with the rapid evolution of this technology, some indications that were off-label in December 2006 are now FDA-approved; these reviews are still included in this summary since they provide insight into the nature of the literature as a whole.

The concept of a disease-specific indication for a drug is fluid. For some drug/disease indications the relationship represents a one-to-one relationship. For others, there are multiple different treatment situations within a disease category such that defining “indication” as the disease in which the drug is used is too broad and makes it difficult to draw conclusions about the data (e.g., alemtuzumab for NHL). Conversely, the indication may need to be sharply narrowed to reflect appropriate use of a drug only in certain times in a disease trajectory (e.g., for refractory disease after prior specified therapy, or in the setting of a positive biomarker). For this report, we used the drug/disease indication as specified within the compendia, since that reflects the indication considered for reimbursement purposes.

## Policy Context

Targeted therapies are increasingly used in cancer treatment because of (1) their potential for improved efficacy in comparison to traditional chemotherapies, and (2) their association with fewer side effects. Heralded as the centerpiece of cancer care of the future, targeted therapies are the subject of a large volume of recent and current research. Research on targeted therapies is proceeding at a rapid pace. Between January 1, 2000, and September 1, 2008, the U.S. Food and Drug Administration (FDA) approved 41 anticancer drugs; 17 of these were targeted agents.1

Like other pharmaceutical treatments, targeted therapies must be approved by the FDA before being prescribed outside of the clinical trial setting. A major purpose of FDA review is to ensure patient safety; the National Cancer Institute Common Toxicity Criteria for Adverse Event reporting (CTCAE) provides standard terminology and definitions for adverse event reporting. Once FDA-approved, however, drugs may be used in new contexts as indicated by the available literature, based on the judgment of the prescribing physician rather than on specific requirements dictated by the FDA. When a drug is prescribed for an indication other than that for which it has obtained FDA approval, the prescription is termed “off-label.” Third-party reimbursement for off-label uses of medications varies. For drugs falling within a category reimbursed by CMS (e.g., injection or Medicare Part D), payment for an off-label use of a drug is guided by whether that drug is listed for the particular off-label indication in one of the approved drug compendia.

Off-label prescribing in oncology is facilitated by Medicare insurability of off-label uses of anticancer drugs and biologics, stipulated under Social Security Act Section 1861(t)(2)(B)(ii)(I) and (II), under the Omnibus Budget Reconciliation Act of 1993. This statute recognized certain compendia as authoritative sources for determining a “medically-accepted indication” of drugs and biological agents used off-label in an anticancer chemotherapeutic regimen, unless the Secretary of Health and Human Services (HHS) determines otherwise. For purposes of the legislation, a compendium was defined as “a comprehensive listing of FDA-approved drugs and biologicals or a comprehensive listing of a specific subset of drugs and biologicals in a specialty compendium” (§414.930). The statute originally indicated that medically-accepted indications would be determined by three designated compendia: American Medical Association Drug Evaluations (AMA-DE), American Hospital Formulary Service Drug Information (AHFS-DI),2 and United States Pharmacopeia Drug Information (USP-DI).3 While the statute pertained specifically to CMS, most other third-party payers and state legislatures have followed suit.4

Implementation of the legislation has shifted in the course of compendia history. The AMA-DE is no longer published; its contents were incorporated into the USP-DI. Publication of the USP-DI ceased in 2007, with contents rolled into a successor compendium, DrugPoints. On June 6, 2008, CMS announced that it would recognize an additional compendium produced by the National Comprehensive Cancer Network (NCCN), the NCCN Drugs & Biologics Compendium, as a mandated reference for establishing coverage policy and coverage decisions regarding the use of drugs and biologics in cancer care. As of the time of this technology assessment report, the current recognized authoritative compendia are: National Comprehensive Cancer Network’s (NCCN) Drugs and Biologics Compendium; Thompson Micromedex’ DrugDex; Elsevier Gold Standard’s Clinical Pharmacology; and American Society of Health-System Pharmacists’ (ASHP) American Hospital Formulary Service-Drug Information (AHFS-DI).5 It should be noted that there is no standardized approach across the various compendia to determining which off-label indications should be included.

Many of the newly developed targeted therapies have been studied, or are currently being studied, for use in disease scenarios other than those for which they originally received FDA approval. Based on this emerging evidence, certain off-label indications are listed in drug compendia; these listings are significant in that oncologists often refer to the compendia when prescribing drugs for off-label uses.

Against this backdrop of off-label prescribing based on compendia listings of non-FDA-approved indications for cancer drugs, CMS requested a technology assessment of the efficacy and safety of selected targeted therapies when prescribed for off-label indications. Given the rapid evolution of this literature, a secondary purpose of the technology assessment was to conduct a horizon scan of early-stage trials (Phase I or prominent preclinical studies) of these agents. This limited horizon scan was intended to complement information gained through systematic review of the current body of literature, and to identify expected future directions. CMS will consider this information as background to its further discussion of coverage for and policies regarding targeted therapies.

## Scope of Study

The scope of this technology assessment is limited to eight targeted therapy drugs and 19 respective off-label indications (Table 1). These drug/indication combinations were derived from a list of all targeted therapy drugs available through the end of 2006. Four compendia – AHFS-DI (2006 version), NCCN Drugs & Biologics Compendium (online version), USP-DI (2006 version), and Clinical Pharmacology (online version) – were searched for listings of off-label indications for these drugs. The drug/indication combinations selected for inclusion in the current technology assessment are those for which these compendia provided clear recommendations. FDA-approved indications of these eight drugs are listed in Table 2.

Table 1 Drugs and off-label indications included in the technology assessment

Targeted therapy | Off-label indication(s)
Alemtuzumab (Campath®) | Cutaneous T-cell lymphoma
Alemtuzumab (Campath®) | Non-Hodgkin lymphoma
Alemtuzumab (Campath®) | T-cell prolymphocytic leukemia
Bevacizumab (Avastin®) | Breast cancer^*^
Bevacizumab (Avastin®) | Epithelial ovarian cancer
Bevacizumab (Avastin®) | Pancreatic adenocarcinoma
Bevacizumab (Avastin®) | Renal cancer^*^
Bortezomib (Velcade®) | Non-Hodgkin lymphoma
Cetuximab (Erbitux®) | Pancreatic adenocarcinoma
Erlotinib (Tarceva®) | Head and neck cancer
Gefitinib (Iressa®) | Head and neck cancer
Imatinib (Gleevec®) | Acute lymphoblastic leukemia^*^
Imatinib (Gleevec®) | Chronic eosinophilic leukemia^*^
Imatinib (Gleevec®) | Dermatofibrosarcoma protuberans^*^
Imatinib (Gleevec®) | Myelodysplastic syndrome^*^
Imatinib (Gleevec®) | Systemic mastocytosis^*^
Rituximab (Rituxan®) | Chronic lymphocytic leukemia
Rituximab (Rituxan®) | Nodular lymphocyte-predominant Hodgkin disease
Rituximab (Rituxan®) | Waldenstrom’s macroglobulinemia^*^

* Indications that were approved by the FDA at some point during the completion of this technology assessment.

Table 2 FDA-approved indications of drugs included in the technology assessment, as of January 2007^*^

Drug | FDA-approved indication(s)
Alemtuzumab (Campath®) | - B-cell chronic lymphocytic leukemia (B-CLL) in patients who have been treated with alkylating agents and who have failed fludarabine therapy
Bevacizumab (Avastin®) | - First-line treatment of patients with metastatic carcinoma of the colon or rectum
Bortezomib (Velcade®) | - Multiple myeloma patients who have received at least one prior therapy; - Relapsed/refractory mantel cell lymphoma
Cetuximab (Erbitux®) | - In combination with radiation therapy, indicated for locally or regionally squamous cell carcinoma of the head and neck. As a single agent, indicated recurrent or metastatic head and neck carcinoma when prior platinum-based therapy has failed.; - In combination with irinotecan, indicated in patients with colorectal carcinoma refractory to irinoctecan-based chemotherapy. As a single agent, indicated for metastatic colorectal carcinoma intolerant to irinotecan-based chemotherapy.
Erlotinib (Tarceva®) | - As a single agent, indicated for locally advanced or metastatic non-small cell lung cancer after failure of at least one prior chemotherapy regimen; - In combination with gemcitabine, indicated for the first-line treatment of patients with locally advanced, unresectable, or metastatic pancreatic cancer
Gefitinib (Iressa®) | - As a single agent, indicated for continued treatment of locally advanced or metastatic non-small cell lung cancer after failure of both platinum-based and docetaxal chemotherapies among patients who are benefiting or have benefited from gefitinib
Imatinib (Gleevec®) | - Kit (CD117) positive unresectable and/or metastatic malignant gastrointestinal stromal tumors GIST; - PH+ CML in chronic phase or in blast crisis, accelerated phase after failure of interferon-alpha therapy, or whose disease has recurred after stem cell transplant, or who are resistant to interferon-alpha therapy
Rituximab (Rituxan®) | - Relapsed or refractory low-grade or follicular, CD20-positive, B-cell, non-Hodgkin’s lymphoma; - First-line treatment of diffuse large B-cell, CD20-positive, non-Hodgkin’s lymphoma in combination with CHOP or other anthracycline-based chemotherapy regimens

* Note: Drugs may be approved for use in combination with other agents not on this list.