# Acronyms and Abbreviations

2-CDA: 2-chlorodeoxyadenosine (cladribine)
4-DHAP: Dexamethasone, high-dose cytarabine, and cisplatin
AC: Doxorubicin and cyclophosphamide
ADE: Adverse drug event
ADR: Adverse drug reaction
AE(s): Adverse event(s)
AF: Atrial fibrillation
AHFS-DI: American Hospital Formulary Service-Drug Information
ALL: Acute lymphoblastic leukemia
Allo: Allograft
AML: Acute myelocytic leukemia
ANC: Absolute neutrophil count
ASCO: American Society of Clinical Oncology
ASCT: Autologous stem cell transplant
ASH: American Society of Hematology
AST/ALT: Aspartate aminotransferase/alanine transaminase
ATP: Adenosine triphosphate
AV: Atrioventricular
BC: Blast crisis
BCVA: Best correct visual acuity
BEAM: Bischloroethylnitrosourea, etoposide, cytarabine, and melphalan
Bili: Bilirubin
BID: Twice daily
BIW: Biweekly
BM: Bone marrow
BMN: Bone marrow necrosis
BMT: Bone marrow transplant
BP: Blood pressure
CA125: Cancer antigen 125
CCR: Clinical complete response
CEL: Chronic eosinophilic leukemia
Chemo: Chemotherapy
CHF: Congestive heart failure
CHOP: Cyclophosphamide, hydroxydaunomycin, Oncovin®, and prednisone
CI: Confidence interval
CLL: Chronic lymphocytic leukemia
CML: Chronic myelogenous leukemia
CMML: Chronic myelomonocytic leukemia
CMV: Cytomegalovirus
CNS: Central nervous system
COG: Children’s Oncology Group
CR: Complete response
CRT: Cathode ray tube
CrCl: Creatinine clearance
CRu: Complete response unconfirmed
CT: Computerized tomography
CTC: Common Toxicity Criteria
CTCL: Cutaneous T-cell lymphoma
CVAD: Cyclophosphamide, vincristine, Adriamycin®, and dexamethasone
CVP: Cyclophosphamide, vincristine, and prednisone
d/c: Discontinued
DCF: Deoxycoformycin
Dexa-BEAM: Dexamethasone, carmustine, etoposide, arabinoside C, and melphalan
DFCI: Dana Farber Consortium Induction
DFS: Disease-free survival
DFSP: Dermatofibrosarcoma protuberans
DHAC: Dexamethasone, cytosine arabinoside, and carboplatin
DHAP: Dexamethasone, high-dose cytarabine, and cisplatin
DIV: Dexamethasone, Imatinib, and vincristine
DLBCL: Diffuse large B-cell lymphoma
DLI: Donor lymphocyte infusion
DVT/PE: Deep vein thrombosis / pulmonary embolism
ECOG: Eastern Collaborative Oncology Group
EGFR: Epidermal growth factor receptor
EOC: Epithelial ovarian cancer
ER: Emergency room
ER: Estrogen receptor
ESHAP: Etoposide, cisplatin, cytarabine, and methylprednisolone
FDA: U.S. Food and Drug Administration
FDG: Fluorodeoxyglucose
FIGO: International Federation of Gynecology and Obstetrics
FMC: Fludarabine phosphate, mitoxantrone, and cyclophosphamide
FP: FIP1L1-PDGFR
GBM: Glioblastoma multiforme
G-CSF: Granulocyte-specific colony-stimulating factor
GGT: Gamma glutamyl transpeptidase
GFLIP: Gemcitabine, irinotecan, fluorouracil followed by leucovorin and cisplatin
GI: Gastrointestinal
GMALL: German Multicenter Study Group for Adult ALL
GVHD: Graft versus host disease
HBV: Hepatitis B virus
HCV: Hepatitis C virus
HER2: Human epidermal growth factor receptor
HES: Hyper eosinophilic syndrome
HG: High grade
HIV: Human immunodeficiency virus
HLA: Human leukocyte antigen
H&N: Head and neck
HNSCC: Head and neck squamous cell cancers
HR-MDS: High-risk myelodysplastic syndrome
HSTCL: Hepatosplenic T-cell non-Hodgkin lymphoma
HSV: Herpes simplex virus
HTN: Hypertension
IBC: Inflammatory breast cancer
ICE: Ifosfamide, carboplatin and etoposide
ICU: Intensive care unit
IFN: Interferon
IgM: Immunoglobulin M
IL: Interleukin
INV: Investigator
IRF: Independent research facility
IV: Intravenous
IVIG: Intravenous immunoglobulin
IWRC: International Workshop Response Criteria
JALSG: Japan Adult Leukemia Study Group
JC: virus John Cunningham virus
KM curve: Kaplan Meier curve
KS: Kaposi Sarcoma
LABC: Locally advanced breast cancer
LDAC: Low-dose Ara-C
LFTs: Liver function tests
LVEF: Left ventricular ejection fraction
LyBC: Lymphoid blast crisis
MALT: Mucosa-associated lymphoid tissue
MCL: Mantle cell lymphoma
MDS: Myelodysplastic syndrome
MF: Mycosis fungoides or myelofibrosis
MI: Myocardial infarction
MINE: Mesna, ifosfamide, mitoxantrone, and etoposide
MM: Multiple myeloma
MRD: Minimal residual disease
MRI: Magnetic resonance imaging
MUD: Marrow unrelated donor
NCCN: National Comprehensive Cancer Network
NCI: National Cancer Institute
NCI-WG: National Cancer Institute-sponsored Working Group
NHL: Non-Hodgkin lymphoma
NK: Natural killer
NLPHD: Nodular lymphocyte predominant Hodgkin’s disease
NMST: Nonmyeloablative allogenic stem cell transplantation
NPC: Nasopharyngeal carcinoma
NR: Not reported
NYHA: New York Heart Association
OIC: Oxaliplatin, irinotecan, and cetuximab
OR: Overall response
ORR: Pverall response rate
OS: Overall survival
PCR: Pathological complete response
PD: Progressive disease
PDGFR: Platelet-derived growth factor receptor
PEG: Percutaneous endoscopic gastrostomy
PET: Positron emission tomography
PFI: Progression-free interval
PFS: Progression-free survival
Ph+: Philadelphia chromosome-positive
PLL: Prolymphocytic leukemia
PML: Progressive multifocal leukoencephalopathy
PO: Orally
PR: Partial response
PR+: Progesterone receptor positive
PS: Performance status
PTL (PTCL): Peripheral T-cell lymphoma
PTLD: Post-transplant lymphoproliferative disorder
PUVA: Photochemotherapy
Q: Every
QoL: Quality of life
RAEB: Refractory anemia with excess blasts
RBC: Red blood cell
RCC: Renal cell carcinoma
R-CHOP: Rituximab, cyclophosphamide, hydroxydaunomycin, Oncovin (vincristine), and prednisone
RCT: Randomized controlled trial
RECIST: Response Evaluation Criteria In Solid Tumors
RFS: Relapse-free survival
RIC: Reduced intensity conditioning
RI-UCBT: Reduced intensity unrelated cord blood transplantation
RPTD: Recommended phase two dose
RR: Response rate
RSC: Reed-Sternberg cells
RT: Radiation therapy
RT-PCR: Reverse transcription polymerase chain reaction
SC or SQ: Subcutaneous
SCC: Squamous cell carcinoma
SCR: Screen
SCT: Stem cell transplant
SCTCL: Subcutaneous T-cell lymphoma
SD: Stable disease
SLE: Systemic lupus erythematosus
SLL: Small lymphocytic lymphoma
SM: Systemic mastocytosis
SUV: Standardized uptake value
TBIL: Total bilirubin
TID: Thrice daily
TIW: Thrice weekly
TK: Tyrosine kinases
TMP/SMS: Trimethoprim/sulfamethoxazole
T-NHL: T-cell non-Hodgkin lymphoma
T-PLL: T-cell prolymphocytic leukemia
TRM: Transplantation-related mortality
TTP: Time to tumor progression
ULN: Per limit of normal
USP-DI: United States Pharmacopeia Drug Information
VCR: Vincristine
VEGF: Vascular endothelial growth factor
VHL: Von Hippel–Lindau
VZV: Varicella zoster virus
WBC: White blood cell
WHO: World Health Organization
WM: Waldenström’s macroglobulinemia
XRT: X-ray therapy
y/o: Year(s) old