# Executive Summary

## Background

The term “targeted therapies” refers to antineoplastic treatments designed not to kill cells but, more precisely, to attack growth factors, cell surface receptors, and intracellular proteins that mediate the cancer cell’s ability to proliferate, grow, or evade cell death. Examples of targeted therapies include small molecule inhibitors, monoclonal antibodies, and conjugated agents. Intended to damage or destroy cancer cells while minimizing the effects on normal cells, several targeted therapies have been successfully brought into routine clinical use, with approval from the U.S. Food and Drug Administration (FDA) for specific indications. The use of these FDA-approved agents has expanded to include multiple indications other than those for which they received FDA approval (i.e., “off-label indications”); in current clinical practice in oncology, off-label prescribing is common.

The primary purpose of this technology assessment is to evaluate the state of the evidence for/against the use of selected targeted therapies for off-label indications. Secondarily, the report also considers the practicality of the traditional systematic review approach, when applied to examine the evidence in rapidly evolving therapeutic areas such as targeted therapies for various cancers.

## Methods

Through review of four drug compendia – the American Society of Health-System Pharmacists’ American Hospital Formulary Service-Drug Information (AHFS-DI; 2006 version); National Comprehensive Cancer Network’s (NCCN) Drugs and Biologics Compendium (online version); United States Pharmacopeia Drug Information (USP-DI; 2006 version); and Elsevier Gold Standard’s Clinical Pharmacology (online version) – 19 off-label indications for eight targeted therapies were identified that were (1) FDA-approved, (2) marketed in or before January 2007, and (3) clearly recommended by at least one of the four compendia. MEDLINE® was searched through September 14, 2007, for potentially relevant publications. Studies were included if they were conducted in humans, investigated one of the 19 drug/disease combinations of interest, and reported at least one of the following outcomes: survival, disease-free survival, tumor response (any criteria acceptable), quality of life, or adverse effects. All study designs were included. This search of the published literature was supplemented by a search for relevant unpublished conference abstracts from the 2006 and 2007 annual meetings of the American Society of Clinical Oncology (ASCO) and the American Society of Hematology (ASH).

Data were abstracted from included journal articles and abstracts directly into summary tables for each drug/disease combination by one investigator and over-read by another. Abstracted data included: study design, phase, selection/randomization, and eligibility criteria; number of patients, median age, previous treatment, stage of disease, drug dose per day, and outcomes sought; tumor response (number with tumor response assessed, complete response, partial response, stable disease, progressive disease); survival (overall, median, disease-free); and adverse events and tolerability. Study quality was assessed in relation to both internal validity (e.g., randomization and allocation concealment; similarity of compared groups at baseline; specification of eligibility criteria; blinding of assessors, care providers, and patients) and external validity (e.g., description of the patient population, similarity to the target population of the report, use of highly selective criteria). In addition to data abstraction and quality analysis, a narrative description of study findings was prepared.

## Results

Results for each of the 19 systematic reviews undertaken for this technology assessment are presented in summary tables in an Appendix to the main report. Here we provide results of the overarching endeavor to describe the state of the evidence for/against the use of targeted therapies for specified off-label indications in oncology.

In this set of systematic reviews of off-label indications for targeted therapies used in oncology, data relevant to the efficacy of any given drug varied greatly in quantity and quality. A high degree of heterogeneity in the data often prevented the combining of data, as required by traditional systematic review methodology, and complicated comparisons of results across studies. The variable and often inadequate quality of available data in this area also impeded efforts to draw definitive conclusions regarding safety or efficacy.

This technology assessment comprised 19 discrete systematic reviews; as such, it represents a large-scale undertaking. A principal difficulty encountered repeatedly was that of establishing a cut-off date for study inclusion. New evidence – with data that might potentially change conclusions, and hence warranted consideration for inclusion – continued to emerge after each of three arbitrarily chosen cut-off dates for study inclusion.

## Discussion

Systematic reviews are not always a feasible and/or reliable way to answer questions regarding clinical effectiveness of new therapies. In areas where the pace of research is rapid, such as targeted therapies for off-label indications in oncology, the sheer volume of research and its heterogeneity make the process of systematic review challenging, if not impossible, within a reasonable timeframe.

In fields where the evidence is rapidly emerging and where the disease or condition entails clinical urgency, timeliness of evidence review is seriously challenged when using traditional systematic review methodology. Systematic reviews require “drawing a line in the sand,” i.e., establishing an arbitrary cut-off date for study inclusion. Publication of new, potentially relevant, studies led the authors of this report to redefine the inclusion period three different times in the effort to include potentially relevant new information. Yet establishing a final cut-off date is eventually a necessity; this means that the results of any systematic review may be out of date even before completion of that review or its publication.

The compendia, a primary source of synthesized evidence for practicing clinical oncologists, are a vital, albeit imperfect, component of current evidence-based practice. The exercise represented by this technology assessment, i.e., the effort to describe the current evidence supporting/refuting the use of targeted therapies, represents an attempt to conduct on a limited scale the task performed by the compendia for the full off-label armamentarium in oncology. The difficulties encountered on the smaller scale of this technology assessment suggest that the compendia’s task is monumental and fraught with challenge. Considering the difficulties inherent in their purpose, the compendia perform an impressive service. Until a tested system is established to ensure access to comprehensive, timely, high-quality data, it is important to work with the compendia to continue to provide clinicians with a source of evidence that can guide their clinical decisions – while recognizing that this evidence synthesis is imperfect.

This technology assessment had several limitations. Variability in the quality and quantity of data made the drawing of conclusions regarding either the efficacy or the safety of the included drugs and respective indications difficult (if possible) and uncertain. Publication bias may have skewed results, because publication of negative results typically lags behind publication of positive results. The literature examined fell within a 10-year window, and reviews may have excluded relevant studies published before or after the endpoints. In particular, the literature reviews did not include published reports indexed in MEDLINE® after September 14, 2007.

Several areas for potential improvement in the current system of evidence development and review emerged through the conduct of this technology assessment. First, better definition of what constitutes “evidence” could help to minimize opinion and subjectivity in the process of evidence reporting. Second, the establishment of a standard approach for reporting on factors relevant to quality (e.g., study phase [e.g., Phase II, Phase III], presence/absence of a control group, blinding) could facilitate critical evaluation and weighting of published evidence. Third, an articulated consensus on the role of comparative effectiveness research in the evaluation of cancer treatments could strengthen both evidence generation and review. Finally, concerted national attention is well-directed toward the development and implementation of a new system for evidence review, one that is designed for rapid learning and expedient translation of research results into clinical practice improvements, and that features evaluation of the comparative effectiveness of available treatments in real-world clinical populations.