# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Al B. Benson III, MD, FACP
  Professor of Medicine
  Robert H. Lurie Comprehensive Cancer Center, Northwestern University
  Chicago, Illinois
- Jennifer L. Malin, MD, PhD
  Member, UCLA Jonsson Comprehensive Cancer Center Patients and Survivors Program Area
  Attending Physician, VA Greater Los Angeles Healthcare System
  Los Angeles, California
- John L. Marshall, MD
  Chief, Division of Hematology/Oncology
  Associate Director for Clinical Research, Lombardi Comprehensive Cancer Center
  Georgetown University Medical Center
  Washington, DC