# References

1 Search of CenterWatch (http://www.centerwatch.com/) conducted 9/2/08 using the term "FDA approval".
2 American Hospital Formulary Service Drug Information® (AHFS-DI®). Bethesda, MD. American Society of Health-System Pharmacists. 2006.
3 Klasco R. United States Pharmacopeia Drug Information® (USP DI®) for the Health Care Professional. Greenwood Village, CO. Thomson Micromedex. 2006.
4 American Society of Clinical Oncology. Reimbursement for cancer treatment: coverage of off-label drug indications. Journal of Clinical Oncology. 24(19):3206-3208.
5 CMS officially recognizes NCCN Drugs & Biologics Compendium(™). Reuters press release. June. 6. 2008. Available at: http://www.reuters.com/article/pressRelease/idUS106853+06-Jun-2008+BW20080606. Accessed August 26, 2009.
6 Wilson JS, Connock M, Song FJ, et al. Imatinib mesylate for the treatment of patients with unresectable and/or metastatic gastrointestinal stromal tumours (GIST). Birmingham. West Midlands Health Technology Assessment Collaboration, University of Birmingham. October. 2003.
7 Khan KS, Ter Reit G, Glanville J, et al. Undertaking systematic reviews of research on effectiveness: CRD's guidance for carrying out or commissioning reviews (2nd edition). CRD Report 4. York. NHS Centre for Reviews and Dissemination, University of York. 2001. Available at: http://www.york.ac.uk/inst/crd/pdf/crdreport4_complete.pdf.
8 Institute of Medicine. Learning what works best: the nation’s need for evidence on comparative effectiveness in health care. Washington, DC. National Academies of Science. September. 2007.
9 Benson A, Lyerley K, Abernethy A, et al. Improving medical decisions through comparative effectiveness research: cancer as a case study. May. 2009. Available at: http://focr.org/files/CER_REPORT_FINAL.pdf. Accessed August 26, 2009.
10 Schwartz R. Cutaneous T-cell Lymphoma. Available at: http://www.emedicine.com/DERM/topic92.htm. 2008.
11 Pinter-Brown L. Lymphoma, cutaneous T-cell. Available at: http://www.emedicine.com/med/TOPIC3486.HTM. 2008.
12 Glass LF, Keller KL, Messina JL, et al. Cutaneous T-cell Lymphoma. Cancer Control. 1998;5(1):11-18. [pmid: 10761012].
13 Dummer R, Assaf C, Bagot M, et al. Maintenance therapy in cutaneous T-cell lymphoma: who, when, what?. European Journal of Cancer. 2007;43(16):2321-2329. [pmid: 17707638].
14 McFarlane V, Friedmann PS, Illidge TM. What's new in the management of cutaneous T-cell lymphoma?. Clinical Oncology. 2005;17(3):174-184. [pmid: 15901002].
15 Criscione VD, Weinstock MA. Incidence of cutaneous T-cell lymphoma in the United States, 1973–2002. Archives of Dermatology. 2007;143(7):854-859. [pmid: 17638728].
16 Lundin J, Hagberg H, Repp R, et al. Phase 2 study of alemtuzumab (anti-CD52 monoclonal antibody) in patients with advanced mycosis fungoides/Sezary syndrome. Blood. 2003;101(11):4267-4272. [pmid: 12543862].
17 Bernengo MG, Quaglino P, Comessatti A, et al. Low-dose intermittent alemtuzumab in the treatment of Sezary syndrome: clinical and immunologic findings in 14 patients. Haematologica. 2007;92(6):784-794. [pmid: 17550851].
18 Ferrajoli A, O'Brien SM, Cortes JE, et al. Phase II study of alemtuzumab in chronic lymphoproliferative disorders. Cancer. 2003;98(4):773-778. [pmid: 12910522].
19 Kennedy GA, Seymour JF, Wolf M, et al. Treatment of patients with advanced mycosis fungoides and Sezary syndrome with alemtuzumab. European Journal of Haematology. 2003;71(4):250-256. [pmid: 12950233].
20 Beltran-Garate B, Huamani-Zavala J, Arones-Valdivia A, et al. Alemtuzumab in patients with advanced mycosis fungoids: First interim report. Blood. 2006;108(11). Abstract #4728.
21 Querfeld C, Rosen S, Guitart J, et al. Alemtuzumab (Campath-1H) in patients with erythrodermic cutaneous T-cell lymphoma (E-CTCL): the Northwestern University Experience. Blood. 2006;108(11). Abstract #2732.
22 Beltran-Garate B, Gomez H, Lopez J, et al. Alemtuzumab in patients with advanced mycosis fungoides and sezary syndrome. Blood. 2007;110(11). Abstract #3425.
23 Porcu P, Baiocchi R, Lin T, et al. A phase I trial of subcutaneous (SQ) dose-escalated alemtuzumab in patients with T-cell lymphoproliferative disorders (T-LPD). Blood. 2007;110(11). Abstract #4317.
24 Bolli N, Di Ianni M, Simonetti S, et al. Treating two concurrent B-cell and T-cell lymphoid neoplasms with alemtuzumab monotherapy. Lancet Oncology. 2004;5(1):64-65.
25 Capalbo S, Delia M, Dargenio M, et al. Mycosis fungoides/Sezary syndrome: a report of three cases treated with Campath-1H as salvage treatment. Medical Oncology. 2003;20(4):389-396. [pmid: 14716037].
26 Gautschi O, Blumenthal N, Streit M, et al. Successful treatment of chemotherapy-refractory Sezary syndrome with alemtuzumab (Campath-1H). European Journal of Haematology. 2004;72(1):61-63. [pmid: 14962265].
27 Goteri G, Rupoli S, Tassetti A, et al. Severe diarrhoea during Campath-1H treatment for refractory cutaneous T-cell lymphoma. Annals of Hematology. 2006;85(9):617-619. [pmid: 16821018].
28 Gutierrez A, Rodriguez J, Ramos R, et al. Treatment with alemtuzumab in a case of refractory primary cutaneous CD30-negative CD8-positive cytotoxic large T-cell lymphoma. European Journal of Haematology. 2004;72(5):377-378. [pmid: 15059077].
29 Lenihan DJ, Alencar AJ, Yang D, et al. Cardiac toxicity of alemtuzumab in patients with mycosis fungoides/Sezary syndrome. Blood. 2004;104(3):655-658. [pmid: 15073032].
30 Lundin J, Kennedy B, Dearden C, et al. No cardiac toxicity associated with alemtuzumab therapy for mycosis fungoides/Sezary syndrome. Blood. 2005;105(10):4148-4149. [pmid: 15867423].
31 Magro CM, Crowson AN, Byrd JC, et al. Atypical lymphocytic lobular panniculitis. Journal of Cutaneous Pathology. 2004;31(4):300-306. [pmid: 15005686].
32 Pawson R, Matutes E, Brito-Babapulle V, et al. Sezary cell leukaemia: a distinct T cell disorder or a variant form of T prolymphocytic leukaemia?. Leukemia. 1997;11(7):1009-1013. [pmid: 9204983].
33 Weder P, Anliker M, Itin P, et al. Familial cutaneous mycosis fungoides: successful treatment with a combination of gemcitabine and alemtuzumab. Dermatology. 2004;208(3):281-283. [pmid: 15118391].
34 Jemal A, Siegel R, Ward E, et al. Cancer statistics, 2007. CA: a Cancer Journal for Clinicians. 2007;57(1):43-66. [pmid: 17237035].
35 Ries L, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975–2005. Available at: http://seer.cancer.gov/csr/1975_2005/. Bethesda, MD. National Cancer Institute. 2008.
36 National Cancer Institute. Adult non-Hodgkin Lymphoma Treatment. Available at: http://www.cancer.gov/cancertopics/pdq/treatment/adult-non-hodgkins/healthprofessional/. 2008.
37 American Cancer Society. Detailed Guide: Lymphoma, non-Hodgkin type. Available at: http://documents.cancer.org/178.00/178.00.pdf. 2007.
38 Cruz RI, Hernandez-Ilizaliturri FJ, Olejniczak S, et al. CD52 over-expression affects rituximab-associated complement-mediated cytotoxicity but not antibody-dependent cellular cytotoxicity: preclinical evidence that targeting CD52 with alemtuzumab may reverse acquired resistance to rituximab in non-Hodgkin lymphoma. Leukemia & Lymphoma. 2007;48(12):2424-2436. [pmid: 18067019].
39 Cull GM, Haynes AP, Byrne JL, et al. Preliminary experience of allogeneic stem cell transplantation for lymphoproliferative disorders using BEAM-CAMPATH conditioning: an effective regimen with low procedure-related toxicity. British Journal of Haematology. 2000;108(4):754-760. [pmid: 10792280].
40 Enblad G, Hagberg H, Erlanson M, et al. A pilot study of alemtuzumab (anti-CD52 monoclonal antibody) therapy for patients with relapsed or chemotherapy-refractory peripheral T-cell lymphomas. Blood. 2004;103(8):2920-2924. [pmid: 15070664].
41 Khorana A, Bunn P, McLaughlin P, et al. A phase II multicenter study of CAMPATH-1H antibody in previously treated patients with nonbulky non-Hodgkin's lymphoma. Leukemia & Lymphoma. 2001;41(1–2):77-87. [pmid: 11342359].
42 Kim JG, Sohn SK, Chae YS, et al. Alemtuzumab plus CHOP as front-line chemotherapy for patients with peripheral T-cell lymphomas: a phase II study. Cancer Chemotherapy & Pharmacology. 2007;60(1):129-134. [pmid: 17406867].
43 Lundin J, Osterborg A, Brittinger G, et al. CAMPATH-1H monoclonal antibody in therapy for previously treated low-grade non-Hodgkin's lymphomas: a phase II multicenter study. European Study Group of CAMPATH-1H Treatment in Low-Grade Non-Hodgkin's Lymphoma. Journal of Clinical Oncology. 1998;16(10):3257-3263. [pmid: 9779699].
44 Tang SC, Hewitt K, Reis MD, et al. Immunosuppressive toxicity of CAMPATH1H monoclonal antibody in the treatment of patients with recurrent low grade lymphoma. Leukemia & Lymphoma. 1996;24(1–2):93-101. [pmid: 9049965].
45 Uppenkamp M, Engert A, Diehl V, et al. Monoclonal antibody therapy with CAMPATH-1H in patients with relapsed high- and low-grade non-Hodgkin's lymphomas: a multicenter phase I/II study. Annals of Hematology. 2002;81(1):26-32. [pmid: 11807632].
46 Ho AYL, Devereux S, Mufti GJ, et al. Reduced-intensity rituximab-BEAM-CAMPATH allogeneic haematopoietic stem cell transplantation for follicular lymphoma is feasible and induces durable molecular remissions. Bone Marrow Transplantation. 2003;31(7):551-557. [pmid: 12692620].
47 Morris E, Mackinnon S. Outcome following alemtuzumab (CAMPATH-1H)-containing reduced intensity allogeneic transplant regimen for relapsed and refractory non-Hodgkin's lymphoma (NHL). Transfusion & Apheresis Science. 2005;32(1):73-83. [pmid: 15737876].
48 Peggs KS, Thomson K, Hart DP, et al. Dose-escalated donor lymphocyte infusions following reduced intensity transplantation: toxicity, chimerism, and disease responses. Blood. 2004;103(4):1548-1556. [pmid: 14576063].
49 Bigelow C, Elkins S, Herrin V, et al. Reduced intensity conditioning regimens with alemtuzumab result in low treatment-related mortality and low relapse rate in unrelated and related allotransplantation recipients. Blood. 2006;108(11). Abstract #5253.
50 Chang K, Lau N, Chew L, et al. Incidence and outcome of T-cell lymphomas in Malaysia. Blood. 2006;108(11). Abstract #4684.
51 Gallamini A, Campidelli C, Zaja F, et al. Lack of correlation between CD-52 expression and treatment outcome in PTCL patients treated with CHOP chemotherapy plus Campath-1h (CHOP-C) as first line treatment. Blood. 2006;108(11). Abstract #4732.
52 Intragumtornchai T, Bunworasate U, Na Nakorn T. Alemtuzumab in combination with CHOP and ESHAP as first-line treatment in peripheral T-cell lymphoma. Blood. 2006;108(11). Abstract #4740.
53 Ravandi-Kashani F, Kantarjian H, Faderl S, et al. Combination therapy with alemtuzumab and pentostatin is effective and has acceptable toxicity in patients with T-lymphoid enoplasms. Blood. 2006;108(11). Abstract #4971.
54 Weidmann E, Hess G, Krause S, et al. A Phase II immunochemotherapy study with alemtuzumab, fludarabine, cyclophosphamide, and doxorubicin (Campath-FCD) in peripheral T-call lymphomas. Blood. 2006;108(11). Abstract #2721.
55 Binder C, Ziepert M, Loeffler M, et al. Final analysis of Phase II study of CHOP/CHOEP-14 followed by consolidation with alemtuzumab in untreated aggressive T-cell lymphomas. Blood. 2007;110(11). Abstract #3431.
56 Thomson K, Morris E, Bloor A, et al. Long-term follow-up of reduced intensity transplantation with an alemtuzumab-containing regimen for aggressive non-Hodgkin's lymphoma. Blood. 2007;110(11). Abstract #1661.
57 Thomson K, Morris E, Milligan D, et al. Extended follow-up of reduced intensity transplantation with an alemtuzumab-containing regimen for follicular lymphoma. Blood. 2007;110(11). Abstract #1666.
58 Aribi A, Kantarjian H, O'Brien S, et al. Combination therapy with alemtuzumab and pentostatin is effective and has acceptable toxicity in patients with T-lymphoid neoplasms. Journal of Clinical Oncology. 2007;25(18S). Abstract #7037.
59 Moon J, Kim J, Sohn S, et al. Alemtuzumab plus CHOP as front-line chemotherapy for patients with peripheral T-cell lymphomas. Journal of Clinical Oncology. 2007;25(18S). Abstract #8069.
60 Sharma K, Wilson W, Dunleavy K, et al. BK viral infections in patients treated with alemtuzumab. Journal of Clinical Oncology. 2007;25(18S). Abstract #3033.
61 Chanan-Khan A, Islam T, Alam A, et al. Long-term survival with allogeneic stem cell transplant and donor lymphocyte infusion following salvage therapy with anti-CD52 monoclonal antibody (Campath) in a patient with alpha/beta hepatosplenic T-cell non-Hodgkin's lymphoma. Leukemia & Lymphoma. 2004;45(8):1673-1675. [pmid: 15370223].
62 Damaj G, Rubio MT, Audard V, et al. Severe cardiac toxicity after monoclonal antibody therapy. European Journal of Haematology. 2002;68(5):324. [pmid: 12144543].
63 Halene S, Zieske A, Berliner N. Sustained remission from angioimmunoblastic T-cell lymphoma induced by alemtuzumab. Nature Clinical Practice Oncology. 2006;3(3):165-168. quiz 169.
64 Martin SI, Marty FM, Fiumara K, et al. Infectious complications associated with alemtuzumab use for lymphoproliferative disorders. Clinical Infectious Diseases. 2006;43(1):16-24. [pmid: 16758413].
65 Mittal S, Milner BJ, Johnston PW, et al. A case of hepatosplenic gamma-delta T-cell lymphoma with a transient response to fludarabine and alemtuzumab. European Journal of Haematology. 2006;76(6):531-534. [pmid: 16548918].
66 Robinson SP, Goldstone AH, Mackinnon S, et al. Chemoresistant or aggressive lymphoma predicts for a poor outcome following reduced-intensity allogeneic progenitor cell transplantation: an analysis from the Lymphoma Working Party of the European Group for Blood and Bone Marrow Transplantation. Blood. 2002;100(13):4310-4316. [pmid: 12393626].
67 Snyder MJ, Stenzel TT, Buckley PJ, et al. Posttransplant lymphoproliferative disorder following nonmyeloablative allogeneic stem cell transplantation. American Journal of Surgical Pathology. 2004;28(6):794-800. [pmid: 15166672].
68 Vivas S, Ruiz de Morales JM, Ramos F, et al. Alemtuzumab for refractory celiac disease in a patient at risk for enteropathy-associated T-cell lymphoma. [erratum appears in N Engl J Med. 2006 Aug 24;355(8):856]. New England Journal of Medicine. 2006;354(23):2514-2515. [pmid: 16760460].
69 Wong R, de Lima M, Couriel D, et al. Treatment of relapsing refractory diffuse large cell lymphoma after matched unrelated donor bone marrow transplant with immunosuppression withdrawal and rituximab. Leukemia & Lymphoma. 2003;44(5):829-832. [pmid: 12802922].
70 Wulf GG, Hasenkamp J, Jung W, et al. Reduced intensity conditioning and allogeneic stem cell transplantation after salvage therapy integrating alemtuzumab for patients with relapsed peripheral T-cell non-Hodgkin's lymphoma. Bone Marrow Transplantation. 2005;36(3):271-273. [pmid: 15937499].
71 Zeitlinger MA, Schmidinger M, Zielinski CC, et al. Effective treatment of a peripheral T-cell lymphoma/lymphoepitheloid cell variant (Lennert's lymphoma) refractory to chemotherapy with the CD-52 antibody alemtuzumab. Leukemia & Lymphoma. 2005;46(5):771-774. [pmid: 16019517].
72 Morris E, Thomson K, Craddock C, et al. Outcomes after alemtuzumab-containing reduced-intensity allogeneic transplantation regimen for relapsed and refractory non-Hodgkin lymphoma. Blood. 2004;104(13):3865-3871. [pmid: 15304395].
73 Matutes E, Brito-Babapulle V, Swansbury J, et al. Clinical and laboratory features of 78 cases of T-prolymphocytic leukemia. Blood. 1991;78(12):3269-3274. [pmid: 1742486].
74 Dearden CE, Matutes E, Cazin B, et al. High remission rate in T-cell prolymphocytic leukemia with CAMPATH-1H. Blood. 2001;98(6):1721-1726. [pmid: 11535503].
75 Matutes E. T-cell Prolymphocytic Leukemia. Cancer Control. 1998;5(1):19-24. [pmid: 10761013].
76 Keating MJ, Flinn I, Jain V, et al. Therapeutic role of alemtuzumab (Campath-1H) in patients who have failed fludarabine: results of a large international study. Blood. 2002;99(10):3554-3561. [pmid: 11986207].
77 Ginaldi L, De Martinis M, Matutes E, et al. Levels of expression of CD52 in normal and leukemic B and T cells: correlation with in vivo therapeutic responses to Campath-1H. Leukemia Research. 1998;22(2):185-191. [pmid: 9593475].
78 Nguyen DD, Cao TM, Dugan K, et al. Cytomegalovirus viremia during Campath-1H therapy for relapsed and refractory chronic lymphocytic leukemia and prolymphocytic leukemia. Clinical Lymphoma. 2002;3(2):105-110. [pmid: 12435283].
79 Pawson R, Dyer MJ, Barge R, et al. Treatment of T-cell prolymphocytic leukemia with human CD52 antibody. Journal of Clinical Oncology. 1997;15(7):2667-2672. [pmid: 9215839].
80 Hopfinger G, Busch R, Eichhorst B, et al. TPLL-1 Protocol of the German CLL Study Group (GCLLSG) - A prospective Phase II trial of fludarabine phosphate, mitoxantrone and Cyclophosphamide (FMC) followed by alemtuzumab consolidation in T-PLL. Blood. 2007;110(11). Abstract #2039.
81 Birhiray RE, Shaw G, Guldan S, et al. Phenotypic transformation of CD52(pos) to CD52(neg) leukemic T cells as a mechanism for resistance to CAMPATH-1H. Leukemia. 2002;16(5):861-864. [pmid: 11986948].
82 Crowley B, Woodcock B. Red cell aplasia due to parvovirus b19 in a patient treated with alemtuzumab. British Journal of Haematology. 2002;119(1):279-280. [pmid: 12358942].
83 Dhar-Munshi S, Alton P, Ayliffe WH. Masquerade syndrome: T-cell prolymphocytic leukemia presenting as panuveitis. American Journal of Ophthalmology. 2001;132(2):275-277. [pmid: 11476701].
84 Dybjer A, Hellquist L, Johansson B, et al. Seropositive polyarthritis and skin manifestations in T-prolymphocytic leukemia/Sezary cell leukemia variant. Leukemia & Lymphoma. 2000;37(3–4):437-440. [pmid: 10752996].
85 Ingram PR, Howman R, Leahy MF, et al. Cryptococcal immune reconstitution inflammatory syndrome following alemtuzumab therapy. Clinical Infectious Diseases. 2007;44(12):e115-e117. [pmid: 17516390].
86 Lee SS, Robinson MR, Morris JC, et al. Conjunctival involvement with T-cell prolymphocytic leukemia: report of a case and review of the literature. Survey of Ophthalmology. 2004;49(5):525-536. [pmid: 15325197].
87 Ravandi F, O'Brien S, Jones D, et al. T-cell prolymphocytic leukemia: a single-institution experience. Clinical Lymphoma & Myeloma. 2005;6(3):234-239. [pmid: 16354329].
88 Tuset E, Matutes E, Brito-Babapulle V, et al. Immunophenotype changes and loss of CD52 expression in two patients with relapsed T-cell prolymphocytic leukaemia. Leukemia & Lymphoma. 2001;42(6):1379-1383. [pmid: 11911422].
89 American Cancer Society. Detailed Guide: Breast Cancer. Available at: http://documents.cancer.org/104.00/104.00.pdf. 2007.
90 Opatt D, Chung C, Wright M, et al. Breast Cancer. Available at: http://www.emedicine.com/plastic/TOPIC521.HTM. 2006.
91 Rugo HS. Bevacizumab in the treatment of breast cancer: rationale and current data. Oncologist. Suppl 1. 2004;9:43-49. [pmid: 15178815].
92 Yang JC, Haworth L, Sherry RM, et al. A randomized trial of bevacizumab, an anti-vascular endothelial growth factor antibody, for metastatic renal cancer. New England Journal of Medicine. 2003;349(5):427-434. [pmid: 12890841].
93 Relf M, LeJeune S, Scott PA, et al. Expression of the angiogenic factors vascular endothelial cell growth factor, acidic and basic fibroblast growth factor, tumor growth factor beta-1, platelet-derived endothelial cell growth factor, placenta growth factor, and pleiotrophin in human primary breast cancer and its relation to angiogenesis. Cancer Research. 1997;57(5):963-969. [pmid: 9041202].
94 Pegram MD, Reese DM. Combined biological therapy of breast cancer using monoclonal antibodies directed against HER2/neu protein and vascular endothelial growth factor. Seminars in Oncology. 2002;29(3 Suppl 11):29-37. [pmid: 12138395].
95 Sledge GW Jr. Vascular endothelial growth factor in breast cancer: biologic and therapeutic aspects. Seminars in Oncology. 2002;29(3 Suppl 11):104-110. [pmid: 12138404].
96 Foekens JA, Peters HA, Grebenchtchikov N, et al. High tumor levels of vascular endothelial growth factor predict poor response to systemic therapy in advanced breast cancer. Cancer Research. 2001;61(14):5407-5414. [pmid: 11454684].
97 Cobleigh MA, Langmuir VK, Sledge GW, et al. A phase I/II dose-escalation trial of bevacizumab in previously treated metastatic breast cancer. Seminars in Oncology. 2003;30(5 Suppl 16):117-124. [pmid: 14613032].
98 Miller KD, Chap LI, Holmes FA, et al. Randomized phase III trial of capecitabine compared with bevacizumab plus capecitabine in patients with previously treated metastatic breast cancer. Journal of Clinical Oncology. 2005;23(4):792-799. [pmid: 15681523].
99 Ramaswamy B, Elias AD, Kelbick NT, et al. Phase II trial of bevacizumab in combination with weekly docetaxel in metastatic breast cancer patients. Clinical Cancer Research. 2006;12(10):3124-3129. [pmid: 16707611].
100 Wedam SB, Low JA, Yang SX, et al. Antiangiogenic and antitumor effects of bevacizumab in patients with inflammatory and locally advanced breast cancer. Journal of Clinical Oncology. 2006;24(5):769-777. [pmid: 16391297].
101 Dickler M, Traina T, Panageas K, et al. Adjuvant (adj) bevacizumab (B) plus dose-dense (dd) doxorubicin/cyclophosphamide (AC) followed by nanoparticle albumin-bound paclitaxel (nab-p) in early stage breast cancer (BC) patients (pts): Cardiac safety. Journal of Clinical Oncology. 2007;25(18S). Abstract #567.
102 Forero-Torres A, Percent I, Galleshaw J, et al. A study of pre-operative (neoadjuvant) letrozole in combination with bevacizumab in past-menopausal women with newly diagnosed operable breast cancer: A preliminary safety report. Journal of Clinical Oncology. 2007;25(18S). Abstract #11020.
103 Mayer E, Miller K, Rugo H, et al. A pilot study of adjuvant bevacizumab after neoadjuvant chemotherapy for high-risk breast cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #561.
104 Rocca A, Dellapasqua S, Pietri E, et al. Metronomic chemotherapy with capecitabine and oral cyclophosphamide in combination with bevacizumab in metastatic breat cancer (mbc): Evidence of activity of an antiangiogenic treatment. Journal of Clinical Oncology. 2007;25(18S). Abstract #11501.
105 Sledge G, Miller K, Moisa C, et al. Safety and efficacy of capecitabine (C) plus bevacizumab (B) as first-line in metastatic breast cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #1013.
106 Swain S, Steinberg S, Modrusan Z, et al. Molecular pathways and gene ontology categories in association with response to combination chemotherapy plus bevacizumab in inflammatory and locally advanced breast cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #509.
107 Amselem L, Cervera E, Diaz-Llopis M, et al. Intravitreal bevacizumab (Avastin) for choroidal metastasis secondary to breast carcinoma: short-term follow-up. Eye. 2007;21(4):566-567. [pmid: 17128202].
108 Handler J. Hypertension complicating cancer chemotherapy. Journal of Clinical Hypertension. 2006;8(7):526-529. [pmid: 16849908].
109 Traina TA, Norton L, Drucker K, et al. Nasal septum perforation in a bevacizumab-treated patient with metastatic breast cancer. Oncologist. 2006;11(10):1070-1071. [pmid: 17110625].
110 Gagné J, Ethier C, Gagné P, et al. Comparative proteome analysis of human epithelial ovarian cancer. Proteome Science. 2007;Vol. 5:16. [pmid: 17892554].
111 American Cancer Society. Detailed Guide: Ovarian Cancer. Available at: http://documents.cancer.org/114.00/114.00.pdf. 2008;Vol. 2008.
112 Cannistra SA. Cancer of the ovary. New England Journal of Medicine. 2004;351(24):2519-2529. [pmid: 15590954].
113 Markman M. New, expanded, and modified use of approved antineoplastic agents in ovarian cancer. Oncologist. 2007;12(2):186-190. [pmid: 17296814].
114 Cannistra SA, Matulonis UA, Penson RT, et al. Phase II study of bevacizumab in patients with platinum-resistant ovarian cancer or peritoneal serous cancer. Journal of Clinical Oncology. 2007;25(33):5180-5186. [pmid: 18024865].
115 Alvarez AA, Krigman HR, Whitaker RS, et al. The prognostic significance of angiogenesis in epithelial ovarian carcinoma. Clinical Cancer Research. 1999;5(3):587-591. [pmid: 10100710].
116 Yamamoto S, Konishi I, Mandai M, et al. Expression of vascular endothelial growth factor (VEGF) in epithelial ovarian neoplasms: correlation with clinicopathology and patient survival, and analysis of serum VEGF levels. British Journal of Cancer. 1997;76(9):1221-1227. [pmid: 9365173].
117 Campos S, Dizon D, Cannistra S, et al. Safety of maintenance bevacizumab after first-line chemotherapy for advanced ovarian and mullerian cancers. Journal of Clinical Oncology. 2007;25(18S). Abstract #5517.
118 Bidus MA, Webb JC, Seidman JD, et al. Sustained response to bevacizumab in refractory well-differentiated ovarian neoplasms. Gynecologic Oncology. 2006;102(1):5-7. [pmid: 16697451].
119 Cohn DE, Valmadre S, Resnick KE, et al. Bevacizumab and weekly taxane chemotherapy demonstrates activity in refractory ovarian cancer. Gynecologic Oncology. 2006;102(2):134-139. [pmid: 16527339].
120 Monk BJ, Han E, Josephs-Cowan CA, et al. Salvage bevacizumab (rhuMAB VEGF)-based therapy after multiple prior cytotoxic regimens in advanced refractory epithelial ovarian cancer. Gynecologic Oncology. 2006;102(2):140-144. [pmid: 16790264].
121 Numnum TM, Rocconi RP, Whitworth J, et al. The use of bevacizumab to palliate symptomatic ascites in patients with refractory ovarian carcinoma. Gynecologic Oncology. 2006;102(3):425-428. [pmid: 16797681].
122 Wright JD, Hagemann A, Rader JS, et al. Bevacizumab combination therapy in recurrent, platinum-refractory, epithelial ovarian carcinoma: A retrospective analysis. Cancer. 2006;107(1):83-89. [pmid: 16736514].
123 American Cancer Society. Detailed Guide: Pancreatic Cancer. Available at: http://documents.cancer.org/116.00/116.00.pdf. 2007.
124 Erickson R. Pancreatic Cancer. Available at: http://www.emedicine.com/med/TOPIC1712.HTM. eMedicine. 2005.
125 Brand RE, Lynch HT. Hereditary pancreatic adenocarcinoma. A clinical perspective. Medical Clinics of North America. 2000;84(3):665-675. [pmid: 10872423].
126 Burris H 3rd, Rocha-Lima C. New therapeutic directions for advanced pancreatic cancer: targeting the epidermal growth factor and vascular endothelial growth factor pathways. Oncologist. 2008;13(3):289-298. [pmid: 18378539].
127 Talar-Wojnarowska R, Malecka-Panas E. Molecular pathogenesis of pancreatic adenocarcinoma: potential clinical implications. Medical Science Monitor. 2006;12(9):RA186-RA193. [pmid: 16940943].
128 Kang SP, Saif MW. Optimal second line treatment options for gemcitabine refractory advanced pancreatic cancer patients. Can we establish standard of care with available data?. Jop: Journal of the Pancreas [Electronic Resource]. 2008;9(2):83-90.
129 Saif MW. New developments in the treatment of pancreatic cancer. Highlights from the "44th ASCO Annual Meeting". Chicago, IL, USA. May 30 – June 3, 2008. Jop: Journal of the Pancreas [Electronic Resource]. 2008;9(4):391-397.
130 Kindler HL, Friberg G, Singh DA, et al. Phase II trial of bevacizumab plus gemcitabine in patients with advanced pancreatic cancer. Journal of Clinical Oncology. 2005;23(31):8033-8040. [pmid: 16258101].
131 Saif MW. Pancreatic cancer: are we moving forward yet? Highlights from the Gastrointestinal Cancers Symposium. Orlando, FL, USA. January 20th, 2007. Jop: Journal of the Pancreas [Electronic Resource]. 2007;8(2):166-176.
132 Anonymous. Gemcitabine plus bevacizumab no better than gemcitabine alone in clinical study of 600 patients with pancreatic cancer. Cancer Biology & Therapy. 2007;6(2):137. [pmid: 17585412].
133 Kindler H, Niedzwiecki D, Hollis D, et al. A Double-blind, placebo-controlled, randomized phase III trial of gemcitabine (G) plus bevacizumab (B) versus gemcitabine plus placebo (P) in patients (pts) with advanced pancreatic cancer (PC): A preliminary analysis of Cancer and Leukemia Group B (CALGB) 80303 [see article #1304/1340 by Saif for data regarding this abstract]. 2007 Gastrointestinal Cancers Symposium (ASCO): American Society of Clinical Oncology (ASCO). 2007.
134 Astsaturov I, Meropol N, Alpaugh R, et al. A randomized phase II and coagulation study of bevacizumab alone or with docetaxel in patients with previously treated metastatic pancreatic adenocarcinoma. Journal of Clinical Oncology. 2007;25(18S). Abstract #4556.
135 Gomez-Martin C, Camara J, Cortes H, et al. A phase I study of erlotinib, bevacizumab and gemcitibine in patients with advanced pancreatic cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #4611.
136 Kim G, Oberg A, Foster N, et al. Phase II trial of bevacizumab, gemcitabine, oxaliplatin in patients with metastatic pancreatic adenocarcinoma. Journal of Clinical Oncology. 2007;25(18S). Abstract #4553.
137 Small W, Mulcahy M, Benson A, et al. A phase II trial of weekly gemcitabine and bevacizumab in combination with abdominal radiation therapy in patients with localized pancreatic cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #15043.
138 Bruckner HW, Hrehorovich VR, Sawhney HS. Bevacizumab as treatment for chemotherapy-resistant pancreatic cancer. Anticancer Research. 2005;25(5):3637-3639. [pmid: 16101193].
139 Crane CH, Ellis LM, Abbruzzese JL, et al. Phase I trial evaluating the safety of bevacizumab with concurrent radiotherapy and capecitabine in locally advanced pancreatic cancer. Journal of Clinical Oncology. 2006;24(7):1145-1151. [pmid: 16505434].
140 Sachdeva K, Makhoul I, Javeed M, et al. Renal Cell Carcinoma. Available at: www.emedicine/MED/topic2002.htm. 2008.
141 Amato RJ. Renal cell carcinoma: review of novel single-agent therapeutics and combination regimens. Annals of Oncology. 2005;16(1):7-15. [pmid: 15598929].
142 American Cancer Society. Detailed Guide: Kidney Cancer (Adult) - Renal Cell Carcinoma. Available at: http://documents.cancer.org/109.00/109.00.pdf. 2007.
143 Godley PA, Taylor M. Renal cell carcinoma. Current Opinion in Oncology. 2001;13(3):199-203. [pmid: 11307065].
144 Motzer RJ, Bacik J, Mazumdar M. Prognostic factors for survival of patients with stage IV renal cell carcinoma: memorial sloan-kettering cancer center experience. Clinical Cancer Research. 2004;10(18 Pt 2):6302S-6303S. [pmid: 15448021].
145 Fossa SD. Interferon in metastatic renal cell carcinoma. Seminars in Oncology. 2000;27(2):187-193. [pmid: 10768597].
146 Rini BI, Small EJ. Biology and clinical development of vascular endothelial growth factor-targeted therapy in renal cell carcinoma. Journal of Clinical Oncology. 2005;23(5):1028-1043. [pmid: 15534359].
147 Stadler WM. Targeted agents for the treatment of advanced renal cell carcinoma. Cancer. 2005;104(11):2323-2333. [pmid: 16240452].
148 Gordon MS, Margolin K, Talpaz M, et al. Phase I safety and pharmacokinetic study of recombinant human anti-vascular endothelial growth factor in patients with advanced cancer. Journal of Clinical Oncology. 2001;19(3):843-850. [pmid: 11157038].
149 Elaraj DM, White DE, Steinberg SM, et al. A pilot study of antiangiogenic therapy with bevacizumab and thalidomide in patients with metastatic renal cell carcinoma. Journal of Immunotherapy. 2004;27(4):259-264. [pmid: 15235386].
150 Hainsworth JD, Sosman JA, Spigel DR, et al. Treatment of metastatic renal cell carcinoma with a combination of bevacizumab and erlotinib. Journal of Clinical Oncology. 2005;23(31):7889-7896. [pmid: 16204015].
151 Ernstoff M, Regan M, McDermott D, et al. First-line treatment with bevacizumab (B) and high dose (HD) bolus aldesleukin (IL-2) in metastatic renal cancer carcinoma (mRCC) patients (pts). Journal of Clinical Oncology. 2007;25(18S). Abstract #15524.
152 Escudier B, Koralewski P, Pluzanska A, et al. A randomized, controlled, double-blind phase III study (AVOREN) of bevacizumab/interferon-a2a vs. placebo/interferon-a2a first-line therapy in metastatic renal cell carcinoma. Journal of Clinical Oncology. 2007;25(18S). Abstract #3.
153 Feldman D, Kondagunta G, Ronnen E, et al. Phase I trial of bevacizumab plus sunitinib in patients (pts) with metastatic renal cell carcinoma (mRCC). Journal of Clinical Oncology. 2007;25(18S). Abstract #5099.
154 Garcia J, Rini B, Mekhail T, et al. A phase II trial of low-dose interlukin (IL-2) and bevacizumab in patients with metastatic renal cell carcinoma (mRCC). Journal of Clinical Oncology. 2007;25(18S). Abstract #5103.
155 Frangie C, Lefaucheur C, Medioni J, et al. Renal thrombotic microangiopathy caused by anti-VEGF-antibody treatment for metastatic renal-cell carcinoma. Lancet Oncology. 2007;8(2):177-178.
156 Glusker P, Recht L, Lane B. Reversible posterior leukoencephalopathy syndrome and bevacizumab. New England Journal of Medicine. 2006;354(9):980-982. discussion 980-2. [pmid: 16510760].
157 Rini BI, Jaeger E, Weinberg V, et al. Clinical response to therapy targeted at vascular endothelial growth factor in metastatic renal cell carcinoma: impact of patient characteristics and Von Hippel-Lindau gene status. BJU International. 2006;98(4):756-762. [pmid: 16827904].
158 Roncone D, Satoskar A, Nadasdy T, et al. Proteinuria in a patient receiving anti-VEGF therapy for metastatic renal cell carcinoma. Nature Clinical Practice Nephrology. 2007;3(5):287-293.
159 Adams J, Palombella VJ, Elliott PJ. Proteasome inhibition: a new strategy in cancer treatment. Investigational New Drugs. 2000;18(2):109-121. [pmid: 10857991].
160 O'Connor OA, Wright J, Moskowitz C, et al. Phase II clinical experience with the novel proteasome inhibitor bortezomib in patients with indolent non-Hodgkin's lymphoma and mantle cell lymphoma. Journal of Clinical Oncology. 2005;23(4):676-684. [pmid: 15613699].
161 Goy A, Younes A, McLaughlin P, et al. Phase II study of proteasome inhibitor bortezomib in relapsed or refractory B-cell non-Hodgkin's lymphoma. Journal of Clinical Oncology. 2005;23(4):667-675. [pmid: 15613697].
162 Blum K, Lucas M, Johnston J, et al. Excessive neurotoxicity in a phase II trial of combined bortezomib and rituximab in patients with relapsed/refractory Mantle Cell (MCL) and Follicular (FL) Non-Hodgkin's Lymphoma. Blood. 2006;108(11). Abstract #2768.
163 De Vos S, Dakhil S, McLaughlin P, et al. Phase II study of bortezomib weekly or twice weekly plus rituximab in patients with Follicular (FL) or Marginal Zone (MZL) Lymphoms: Final results. Blood. 2006;108(11). Abstract #694.
164 Dhillon N, Bakkannagari S, Ng C, et al. Cutaneous T-cell lymphoma: Responses in Phase I trial of combination therapy with liposomal doxorubicin, bortezomib, and gemcitabine. Blood. 2006;108(11). Abstract #2466.
165 Gerecitano J, Portlock C, Noy A, et al. The schedule dependent combination of bortezomib (Bor) with Rituximab (R), cyclophosphamide (C) and prednisone (P) produces minimal toxicity, even at relatively high doses of proteasome inhibitor, in patients with relapsed/refractory indolent B-cell lymphomproliferative disorders. Blood. 2006;108(11). Abstract #2759.
166 Treon S, Soumerai J, Patterson C, et al. Bortezomib, dexamethasone and rituximab (BDR) is a highly active regimen in the primary therapy of Waldenstrom's Macroglobulinemia: Planned interim results of WMCTG clinical trial 05-180. Blood. 2006;108(11). Abstract #2765.
167 Zinzani P, Tani M, Musuraca G, et al. Phase II study of proteasome inhibitor bortezomib (Velcade®) in patients with relapsed/refractory T-cell lymphoma: Preliminary results. Blood. 2006;108(11). Abstract #2462.
168 Abbadessa A, Monaco G, Troiano M, et al. Long term disease free survival in patient with linfoplasmocytic cymphoma and regression of associated severe renal failure after treatment with bortezomib. Blood. 2007;110(11). Abstract #4477.
169 Agathocleous A, Rule S, Johnson P, et al. Preliminary results of a phase I/II study of weekly or twice weekly Bortezomib in combination with Rituximab, in patients with Follicular Lymphoma, Mantle Cell Lymphoma and Waldenstrom's Macroglobulinemia. Blood. 2007;110(11). Abstract #2559.
170 Conconi A, Lopez-Guillermo A, Martinelli G, et al. IELSG phase II studies of bortezomib in Malt Lymphomas. Blood. 2007;110(11). Abstract #2580.
171 Ghobrial I, Padmanabhan S, Badros A, et al. Phase II trial of combination of bortezomib and rituximab in relapsed and/or refractory Waldenstrom Macroglobulinemia: Preliminary results. Blood. 2007;110(11). Abstract #4494.
172 Jang G, Sym S-J, Kim S, et al. A phase I trial of bortezomib plus CHOP every 2 weeks in patients with advanced stage diffuse large B-cell lymphomas. Blood. 2007;110(11). Abstract #4446.
173 Leonard J, Furman R, Cheung Y, et al. CHOP-R = bortezomib as initial therapy for diffuse large B-cell lymphoma (DLBCL). Journal of Clinical Oncology. 2007;25(18S). Abstract #8031.
174 Mounier N, Ribrag V, Haioun C, et al. Efficacy and toxicity of two schedules of R-CHOP plus bortezomib in frint-line B lymphoma patients: A randomized phase II trial from the Groupe d'Etude des Lymphomes de l'Adulte (GELA). Journal of Clinical Oncology. 2007;25(18S). Abstract #8010.
175 O'Connor O, Hamlin P, Moskowitz C, et al. Schedule of bortezomib administration may be an important determinant of single-agent activity in patients with relapsed or refractory follicular (FL) lymphoma and mantle cell lymphoma (MCL). Journal of Clinical Oncology. 2007;25(18S). Abstract #8051.
176 Enrico O, Gabriele B, Nadia C, et al. Unexpected cardiotoxicity in haematological bortezomib treated patients. British Journal of Haematology. 2007;138(3):396-397. [pmid: 17561972].
177 Gerecitano J, Goy A, Wright J, et al. Drug-induced cutaneous vasculitis in patients with non-Hodgkin lymphoma treated with the novel proteasome inhibitor bortezomib: a possible surrogate marker of response?. British Journal of Haematology. 2006;134(4):391-398. [pmid: 16882131].
178 Mai W, Meng H, Jin J, et al. Treatment with bortezomib in a patient with heavily pretreated refractory T-cell lymphoblastic lymphoma. European Journal of Haematology. 2006;77(5):445-447. [pmid: 16930138].
179 Stubblefield MD, Slovin S, MacGregor-Cortelli B, et al. An electrodiagnostic evaluation of the effect of pre-existing peripheral nervous system disorders in patients treated with the novel proteasome inhibitor bortezomib. Clinical Oncology (Royal College of Radiologists). 2006;18(5):410-418.
180 Tong Y, Qian J, Li Y, et al. The high incidence of varicella herpes zoster with the use of bortezomib in 10 patients. American Journal of Hematology. 2007;82(5):403-404. [pmid: 17133426].
181 Krempien R, Muenter MW, Huber PE, et al. Randomized phase II--study evaluating EGFR targeting therapy with cetuximab in combination with radiotherapy and chemotherapy for patients with locally advanced pancreatic cancer--PARC: study protocol [ISRCTN56652283]. BMC Cancer. 2005;5:131. [pmid: 16219105].
182 Baumann M, Krause M. Targeting the epidermal growth factor receptor in radiotherapy: radiobiological mechanisms, preclinical and clinical results. Radiotherapy & Oncology. 2004;72(3):257-266. [pmid: 15450723].
183 Xiong HQ, Abbruzzese JL. Epidermal growth factor receptor-targeted therapy for pancreatic cancer. Seminars in Oncology. 2002;29(5 Suppl 14):31-37. [pmid: 12422311].
184 Xiong HQ, Rosenberg A, LoBuglio A, et al. Cetuximab, a monoclonal antibody targeting the epidermal growth factor receptor, in combination with gemcitabine for advanced pancreatic cancer: a multicenter phase II Trial. Journal of Clinical Oncology. 2004;22(13):2610-2616. [pmid: 15226328].
185 Burtness B, Powell M, Berlin J, et al. Phase II trial of irinotecan/docetaxel for advanced pancreatic cancer with randomization between irinotecan/docetaxel and irinotecan/docetaxel plus C225, a monoclonal antibody to the epidermal growth factor receptor (EGF-r): Eastern Cooperative Oncology. Journal of Clinical Oncology. 2007;25(18S). Abstract #4519.
186 Cascinu S, Berardi R, Siena S, et al. The impact of cetuximab on the gemcitabine/cisplatin combination in first-line treatment of EGFR-positive advanced pancreatic cancer (APC): A randomized phase II trial of GISCAD. Journal of Clinical Oncology. 2007;25(18S). Abstract #4544.
187 Dudek A, Gada P, Mulamalla K, et al. Phase I study of bortezomib plus cetuximab in patients with tumors expressing epidermal growth factor receptor (EGFR). Journal of Clinical Oncology. 2007;25(18S). Abstract #18143.
188 Krempien R, Munter M, Timke C, et al. Cetuximab in combination with intensity modulated radiotherapy (IMRT) and gemcitabine for patients with locally advanced pancreatic cancer: A prospective phase II trial [PARC-Study ISRCTN56652283]. Journal of Clinical Oncology. 2007;25(18S). Abstract #4573.
189 Kullmann F, Hollerbach S, Dollinger M, et al. Cetuximab plus gemcitabine/oxaliplatin (GEMOXCET) in 1stline metastatic pancreatic cancer. First results from a multicenter phase II study. [see #1304/1340 by Saif for data from this abstract]. 2007 Gastrointestinal Cancers Symposium (ASCO): American Society of Clinical Oncology (ASCO). 2007.
190 Lee F, Roach M, Duong L, et al. Improved survival with combination oxaliplatin, irinotecan, cetuximab for metastatic pancreatic cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #15180.
191 Needle MN. Safety experience with IMC-C225, an anti-epidermal growth factor receptor antibody. Seminars in Oncology. 2002;29(5 Suppl 14):55-60. [pmid: 12422314].
192 de la Torre J, Joseph E. Head and neck cancer: Squamous cell carcinoma. Available at: http://www.emedicine.com/plastic/TOPIC376.HTM. 2006.
193 National Cancer Institute. Head and Neck Cancer: Questions and Answers. Available at: http://www.cancer.gov/cancertopics/factsheet/Sites-Types/head-and-neck. 2005.
194 Carvalho AL, Nishimoto IN, Califano JA, et al. Trends in incidence and prognosis for head and neck cancer in the United States: a site-specific analysis of the SEER database. International Journal of Cancer. 2005;114(5):806-816.
195 Murata M, Takayama K, Choi BC, et al. A nested case-control study on alcohol drinking, tobacco smoking, and cancer. Cancer Detection & Prevention. 1996;20(6):557-565. [pmid: 8939341].
196 Zhang Q, Bhola NE, Lui VWY, et al. Antitumor mechanisms of combined gastrin-releasing peptide receptor and epidermal growth factor receptor targeting in head and neck cancer. Molecular Cancer Therapeutics. 2007;6(4):1414-1424. [pmid: 17431120].
197 Gourin CG, Podolsky RH. Racial disparities in patients with head and neck squamous cell carcinoma. [erratum appears in Laryngoscope. 2006 Nov;116(11):2098]. Laryngoscope. 2006;116(7):1093-1106. [pmid: 16826042].
198 Rubin Grandis J, Melhem MF, Gooding WE, et al. Levels of TGF-alpha and EGFR protein in head and neck squamous cell carcinoma and patient survival. Journal of the National Cancer Institute. 1998;90(11):824-832. [pmid: 9625170].
199 Rocha-Lima CM, Soares HP, Raez LE, et al. EGFR targeting of solid tumors. Cancer Control. 2007;14(3):295-304. [pmid: 17615536].
200 Bareschino MA, Schettino C, Troiani T, et al. Erlotinib in cancer treatment. Annals of Oncology. Suppl 6. 2007;18:vi35-vi41. [pmid: 17591829].
201 Siu LL, Soulieres D, Chen EX, et al. Phase I/II trial of erlotinib and cisplatin in patients with recurrent or metastatic squamous cell carcinoma of the head and neck: a Princess Margaret Hospital phase II consortium and National Cancer Institute of Canada Clinical Trials Group Study. Journal of Clinical Oncology. 2007;25(16):2178-2183. [pmid: 17538162].
202 Soulieres D, Senzer NN, Vokes EE, et al. Multicenter phase II study of erlotinib, an oral epidermal growth factor receptor tyrosine kinase inhibitor, in patients with recurrent or metastatic squamous cell cancer of the head and neck. Journal of Clinical Oncology. 2004;22(1):77-85. [pmid: 14701768].
203 Arias de la Vega F, Herruzo I, de las Heras M, et al. Phase I/II study of concurrent erlotinib and chemoradiation for post-resected locally advanced squamous head and neck cancer (HNSCC): A GICOR study. Journal of Clinical Oncology. 2007;25(18S). Abstract #16544.
204 Herchenhorn D, Dias F, Pineda R, et al. Phase II study of erlotinib combined with cisplatin and radiotherapy for locally advanced squamous cell carcinoma of the head and neck (SCCHN). Journal of Clinical Oncology. 2007;25(18S). Abstract #6033.
205 Kim E, Kies M, Glisson B, et al. Final results of a phase II study of erlotinib, docetaxel and cisplatin in patients with recurrent/metastatic head and neck cancer. Journal of Clinical Oncology. 2007;25(18S). Abstract #6013.
206 Seiwert T, Davis D, Yan D, et al. pKDR/KDR ratio predicts response in a phase I/II pharmacodynamic study of erlotinib and bevacizumab for recurrent or metastatic head and neck cancer (HNC). Journal of Clinical Oncology. 2007;25(18S). Abstract #6021.
207 Cohen EEW, Kane MA, List MA, et al. Phase II trial of gefitinib 250 mg daily in patients with recurrent and/or metastatic squamous cell carcinoma of the head and neck. Clinical Cancer Research. 2005;11(23):8418-8424. [pmid: 16322304].
208 Cohen EEW, Rosen F, Stadler WM, et al. Phase II trial of ZD1839 in recurrent or metastatic squamous cell carcinoma of the head and neck. Journal of Clinical Oncology. 2003;21(10):1980-1987. [pmid: 12743152].
209 Kirby AM, A'Hern RP, D'Ambrosio C, et al. Gefitinib (ZD1839, Iressa) as palliative treatment in recurrent or metastatic head and neck cancer. British Journal of Cancer. 2006;94(5):631-636. [pmid: 16495923].
210 Ahmed S, Cohen E, Haraf D, et al. Updated results of a phase II trial integrating gefitinib (G) into concurrent chemoradiation (CRT) followed by G adjuvant therapy for locally advanced head and neck cancer (HNC). Journal of Clinical Oncology. 2007;25(18S). Abstract #6028.
211 Chua D, Sham J, Au G. A phase II trial of gefitinib in recurrent and metastatic nasopharyngeal carcinoma pretreated with platinum-based chemotherapy. Journal of Clinical Oncology. 2007;25(18S). Abstract #6042.
212 Morris J, Allen C, Citrin D, et al. Pilot phase I study of gefitinib (GEF) in combination with paclitaxel (PAC) and radiationt herapy (RT) in patients with locally advanced head and neck squamous cell carcinoma (HNSCC) and effects on epidermal growth factor receptor (EGFR) signaling pathway. Journal of Clinical Oncology. 2007;25(18S). Abstract #16526.
213 Rueda A, Medina J, Mesia R, et al. Gefitinib plus concomitant boost accelerated radiation (AFX-CB) and concurrent weekly cisplatin for locally advanced unresectable squamous cell head and neck carcinomas (SCCHN): A phase II study. Journal of Clinical Oncology. 2007;25(18S). Abstract #6031.
214 Weber R, Lustig R, Glisson B, et al. A phase II trial of ZD 1869 for advanced cutaneous squamous cell carcinoma of the head and neck. Journal of Clinical Oncology. 2007;25(18S). Abstract #6038.
215 Baselga J, Rischin D, Ranson M, et al. Phase I safety, pharmacokinetic, and pharmacodynamic trial of ZD1839, a selective oral epidermal growth factor receptor tyrosine kinase inhibitor, in patients with five selected solid tumor types. Journal of Clinical Oncology. 2002;20(21):4292-4302. [pmid: 12409327].
216 Herbst RS, Maddox A-M, Rothenberg ML, et al. Selective oral epidermal growth factor receptor tyrosine kinase inhibitor ZD1839 is generally well-tolerated and has activity in non-small-cell lung cancer and other solid tumors: results of a phase I trial. Journal of Clinical Oncology. 2002;20(18):3815-3825. [pmid: 12228201].
217 Lorusso PM. Phase I studies of ZD1839 in patients with common solid tumors. Seminars in Oncology. 2003;30(1 Suppl 1):21-29. [pmid: 12644981].
218 Wirth LJ, Haddad RI, Lindeman NI, et al. Phase I study of gefitinib plus celecoxib in recurrent or metastatic squamous cell carcinoma of the head and neck. Journal of Clinical Oncology. 2005;23(28):6976-6981. [pmid: 16172459].
219 Seiter K. Acute Lymphoblastic Leukemia. Available at: http://www.emedicine.com/med/TOPIC34.HTM. 2006.
220 Esparza S, Sakamoto K. Topics in pediatric leukemia: Acute lymphoblastic leukemia. Available at: http://www.pubmedcentral.nih.gov/articlerender.fcgi?artid=1681386. 2005.
221 American Cancer Society. Detailed Guide: Leukemia - acute lymphocytic. Available at: http://documents.cancer.org/6891.00/6891.00.pdf. 2007.
222 National Cancer Institute. Aculte lymphoblastic leukemia in children. Available at: http://www.cancer.gov/cancertopics/factsheet/ALLinchildren. 2002.
223 Druker BJ, Sawyers CL, Kantarjian H, et al. Activity of a specific inhibitor of the BCR-ABL tyrosine kinase in the blast crisis of chronic myeloid leukemia and acute lymphoblastic leukemia with the Philadelphia chromosome. [erratum appears in N Engl J Med 2001 Jul 19;345(3)232]. New England Journal of Medicine. 2001;344(14):1038-1042. [pmid: 11287973].
224 Greaves M. Childhood leukaemia. BMJ. 2002;324(7332):283-287. [pmid: 11823363].
225 Radich JP. Philadelphia chromosome-positive acute lymphocytic leukemia. Hematology - Oncology Clinics of North America. 2001;15(1):21-36.
226 de Labarthe A, Rousselot P, Huguet-Rigal F, et al. Imatinib combined with induction or consolidation chemotherapy in patients with de novo Philadelphia chromosome-positive acute lymphoblastic leukemia: results of the GRAAPH-2003 study. Blood. 2007;109(4):1408-1413. [pmid: 17062730].
227 Delannoy A, Delabesse E, Lheritier V, et al. Imatinib and methylprednisolone alternated with chemotherapy improve the outcome of elderly patients with Philadelphia-positive acute lymphoblastic leukemia: results of the GRAALL AFR09 study. Leukemia. 2006;20(9):1526-1532. [pmid: 16838024].
228 Lee KH, Lee JH, Choi SJ, et al. Clinical effect of imatinib added to intensive combination chemotherapy for newly diagnosed Philadelphia chromosome-positive acute lymphoblastic leukemia. Leukemia. 2005;19(9):1509-1516. [pmid: 16034462].
229 Lee S, Kim Y-J, Min C-K, et al. The effect of first-line imatinib interim therapy on the outcome of allogeneic stem cell transplantation in adults with newly diagnosed Philadelphia chromosome-positive acute lymphoblastic leukemia. Blood. 2005;105(9):3449-3457. [pmid: 15657178].
230 Ottmann OG, Druker BJ, Sawyers CL, et al. A phase 2 study of imatinib in patients with relapsed or refractory Philadelphia chromosome-positive acute lymphoid leukemias. Blood. 2002;100(6):1965-1971. [pmid: 12200353].
231 Scheuring UJ, Pfeifer H, Wassmann B, et al. Early minimal residual disease (MRD) analysis during treatment of Philadelphia chromosome/Bcr-Abl-positive acute lymphoblastic leukemia with the Abl-tyrosine kinase inhibitor imatinib (STI571). Blood. 2003;101(1):85-90. [pmid: 12393581].
232 Ottmann OG, Wassmann B, Pfeifer H, et al. Imatinib Compared with Chemotherapy as Front-Line Treatment of Elderly Patients With Philadelphia Chromosome-Positive Acute Lymphoblastic Leukemia (Ph+ALL). Cancer. 2007;109(10):2068-2076. [pmid: 17429836].
233 Rea D, Legros L, Raffoux E, et al. High-dose imatinib mesylate combined with vincristine and dexamethasone (DIV regimen) as induction therapy in patients with resistant Philadelphia-positive acute lymphoblastic leukemia and lymphoid blast crisis of chronic myeloid leukemia. Leukemia. 2006;20(3):400-403. [pmid: 16437142].
234 Towatari M, Yanada M, Usui N, et al. Combination of intensive chemotherapy and imatinib can rapidly induce high-quality complete remission for a majority of patients with newly diagnosed BCR-ABL-positive acute lymphoblastic leukemia. Blood. 2004;104(12):3507-3512. [pmid: 15315963].
235 Vignetti M, Fazi P, Cimino G, et al. Imatinib plus steroids induces complete remissions and prolonged survival in elderly Philadelphia chromosome-positive patients with acute lymphoblastic leukemia without additional chemotherapy: results of the Gruppo Italiano Malattie Ematologiche dell'Adulto (GIMEMA) LAL0201-B protocol. Blood. 2007;109(9):3676-3678. [pmid: 17213285].
236 Wassmann B, Pfeifer H, Goekbuget N, et al. Alternating versus concurrent schedules of imatinib and chemotherapy as front-line therapy for Philadelphia-positive acute lymphoblastic leukemia (Ph+ ALL). Blood. 2006;108(5):1469-1477. [pmid: 16638934].
237 Yanada M, Takeuchi J, Sugiura I, et al. High complete remission rate and promising outcome by combination of imatinib and chemotherapy for newly diagnosed BCR-ABL-positive acute lymphoblastic leukemia: a phase II study by the Japan Adult Leukemia Study Group. Journal of Clinical Oncology. 2006;24(3):460-466. [pmid: 16344315].
238 Cimino G, Elia L, Pane F, et al. High levels of tumor load reduction after intensive chemotherapy favorably affect the prognosis of BCR/ABL+ ALL patients receiving Imatinib Mesylate alone as a post-consolidation treatment according to the Italian GIMEMA LAL 0201/A protocol. Blood. 2006;108(11). Abstract #638.
239 Leguay T, Witz F, De Botton S, et al. Post-remission therapy with Imatinib and HAM improve MRD before transplant for patients with Philadelphia-positive Aculte Lymphoblastic Leukemia (Ph+ALL): Results of the GRAALL AFR01 study. Blood. 2006;108(25). Abstract #1877.
240 Pfeifer H, Wassmann B, Pavlova A, et al. Bcr-Abl Tyrosine Kinase domain mutations both pre-exist and develop during Imatinib treatment and are responsible for resistance in patients with Philadelphia-Chromosome Positive Acute Lymphoblastic Leukemia (Ph+ALL). Blood. 2006;108(11). Abstract #639.
241 Schultz K, Aledo A, Bowman W, et al. Minimal toxicity of Imatinib Mesylate in combination with intensive chemotherapy for Philadelphia Chromosome Positive (Ph+) Acute Lymphoblastic Leukemia (ALL) in children: A report of the Children's Oncology Group (COG) AALL0031 Protocol for Very High Risk ALL. Blood. 2006;108(11). Abstract # 283.
242 Thomas D, Kantarjian H, Cortes J, et al. Outcome with the Hyper-CVAD and Imatinib Mesylate regimen as frontline therapy for Adult Philadelphia (Ph) positive acute lymphocytic leukemia (ALL). Blood. 2006;108(11). Abstract #284.
243 Fielding A, Richards S, Lazarus H, et al. Does Imatinib change the outcome in Philadelphia Chromosome Positive Acute Lymphoblastic Leukemia in adults? Data from the UKALLXII/ECOG2993 Study. Blood. 2007;110(11). Abstract #8.
244 Mukhopadhyay A, Mukhopadhyay S, Gupta P, et al. Imatinib plus vincristin & prednisolone induces complete remission and prolonged survival in elderly Philadelphia Chromosome Positive Acule Lymphoblastic Leukemia patients. Blood. 2007;110(11). Abstract #4339.
245 Pfeifer H, Wassmann B, Wystub S, et al. Treatment outcome with Imatinib-based maintenance therapy in elderly patients with Philadelphia-Positive Acute Lymphoblastic Leukemia (Ph_ALL) ineligible for allogeneic stem cell transplantation (SCT). Blood. 2007;110(11). Abstract #2817.
246 Rousselot P, Huguet F, Vey N, et al. Maintenance therapy by Glivec (R) and Pegasys (R) in patients with Philadelphia Positive Acute Lymphocytic Leukemia not eligible for hematopoietic stem cell transplantation. Blood. 2007;110(11). Abstract #2812.
247 Rousselot P, Recher C, Buzyn A, et al. Results of the AFR07 prospective study in de novo Philadelphia Positive ALL patients over 55 years: Efficacy and safety of a Glivec (R) based induction followed by maintenance therapy with Glivec (R) and Pegasys (R). Blood. 2007;110(11). Abstract #2816.
248 Schultz K, Bowman W, Slayton W, et al. Improved early event free survival, (EFS) in children with Philadelphia Chromosome-Positive (Ph+) Acute Lymphoblastic Leukemia (ALL) with intensive Imatinib in combination with high dose chemotherapy: Children's Oncology Group (COG) Study AALL0031. Blood. 2007;110(11). Abstract #4.
249 Suzuki T, Abe Y, Mori Y, et al. Successful management of pregnancy and remission-induction of a patient with Philadelphia Chromosome-Positive Acute Lymphoblastic Leukemia (Ph+ALL) by means of Imatinib Myselate and HyperCVAD. Blood. 2007;110(11). Abstract #4327.
250 Thomas D, Kantarjian H, Ravandi F, et al. Long-term follow-up after frontline therapy with the Hyper-CVAD and Imatinib Mesylate regimen in adults with Philadelphia (Ph) positive acute lymphocytic leukemia (ALL). Blood. 2007;110(11). Abstract #9.
251 Wetzler M, Stock W, Donohue K, et al. Autologous stem cell transplantation (SCT) following sequential chemotherapy and Imatinib for adults with newly diagnosed Philadelphia Chromosome Positive Acute Lymphoblastic Leukemia (Ph+ALL) - CALBG Study 10001. Blood. 2007;110(11). Abstract #2869.
252 Yanada M, Takeuchi J, Sugiura I, et al. Factors associated with relapse-free survival in patients with Philadelphia Chromosome-Positive Acule Lymphoblastic Leukemia treated with Imatinib-combined chemotherapy. Blood. 2007;110(11). Abstract #2813.
253 Anonymous. Gleevec may be heart toxic. Health News. 2007;13(1):2.
254 Baron F, Frere P, Fillet G, et al. Treatment of leukemia relapse after allogeneic hematopoietic stem cell transplantation by donor lymphocyte infusion and STI-571. Haematologica. 2001;86(9):993-994. [pmid: 11532632].
255 Brandwein JM, Gupta V, Wells RA, et al. Treatment of elderly patients with acute lymphoblastic leukemia--evidence for a benefit of imatinib in BCR-ABL positive patients. Leukemia Research. 2005;29(12):1381-1386. [pmid: 15927253].
256 Bujassoum S, Rifkind J, Lipton JH. Isolated central nervous system relapse in lymphoid blast crisis chronic myeloid leukemia and acute lymphoblastic leukemia in patients on imatinib therapy. Leukemia & Lymphoma. 2004;45(2):401-403. [pmid: 15101732].
257 Dann EJ, Fineman R, Rowe JM. Tumor lysis syndrome after STI571 in Philadelphia chromosome-positive acute lymphoblastic leukemia. Journal of Clinical Oncology. 2002;20(1):354-355. [pmid: 11773197].
258 De Vita S, De Matteis S, Laurenti L, et al. Imatinib for secondary Ph+ acute lymphoblastic leukemia induces response in concomitant GBM. Annals of Oncology. 2006;17(4):720-721. [pmid: 16263757].
259 Dogra S, Kanwar AJ. Imatinib mesylate-induced maculopapular drug rash. National Medical Journal of India. 2003;16(5):285-286. [pmid: 14680290].
260 Fruehauf S, Topaly J, Buss EC, et al. Combination of imatinib and established antileukemic treatment modalities for otherwise refractory BCR-ABL positive lymphoblastic leukemia. Haematologica. 2002;87(12):ECR38. [pmid: 12495909].
261 Gupta V, Kamel-Reid S, Minden MD, et al. Imatinib Mesylate (Gleevec) is a useful agent in the salvage treatment of adults with relapsed/refractory Philadelphia positive acute leukemias. Hematology. 2003;8(3):139-143. [pmid: 12745646].
262 Houot R, Tavernier E, Le Q-H, et al. Philadelphia chromosome-positive acute lymphoblastic leukemia in the elderly: prognostic factors and treatment outcome. Hematology. 2004;9(5–6):369-376. [pmid: 15763976].
263 Hurtado-Sarrio M, Duch-Samper A, Taboada-Esteve J, et al. Anterior chamber infiltration in a patient with Ph+ acute lymphoblastic leukemia in remission with imatinib. American Journal of Ophthalmology. 2005;139(4):723-724. [pmid: 15808178].
264 Ishii Y, Shoji N, Kimura Y, et al. Prominent pleural effusion possibly due to imatinib mesylate in adult Philadelphia chromosome-positive acute lymphoblastic leukemia. Internal Medicine. 2006;45(5):339-340. [pmid: 16596010].
265 Lahaye T, Riehm B, Berger U, et al. Response and resistance in 300 patients with BCR-ABL-positive leukemias treated with imatinib in a single center: a 4.5-year follow-up. Cancer. 2005;103(8):1659-1669. [pmid: 15747376].
266 Leis JF, Stepan DE, Curtin PT, et al. Central nervous system failure in patients with chronic myelogenous leukemia lymphoid blast crisis and Philadelphia chromosome positive acute lymphoblastic leukemia treated with imatinib (STI-571). Leukemia & Lymphoma. 2004;45(4):695-698. [pmid: 15160941].
267 Matsue K, Takeuchi M, Koseki M, et al. Bone marrow necrosis associated with the use of imatinib mesylate in a patient with Philadelphia chromosome-positive acute lymphoblastic leukemia. Annals of Hematology. 2006;85(8):542-544. [pmid: 16570152].
268 Morgensztern D, Rosado MF, Raez LE, et al. Combination of imatinib and cytarabine for the treatment of Philadelphia chromosome positive acute lymphoblastic leukemia. Leukemia & Lymphoma. 2005;46(2):297-298. [pmid: 15621818].
269 Nakajima A, Tauchi T, Ohyashiki K. ABL-specific tyrosine kinase inhibitor, STI571 in vitro, affects Ph-positive acute lymphoblastic leukemia and chronic myelogenous leukemia in blastic crisis. Leukemia. 2001;15(6):989-990. [pmid: 11417489].
270 Nishii K, Sakakura M, Tsukada T, et al. Successful treatment with imatinib combined with less intensive chemotherapy (vincristine and dexamethasone) as induction therapy in a very elderly patient with Philadelphia chromosome-positive acute lymphoblastic leukemia. International Journal of Hematology. 2007;85(3):273-274. [pmid: 17483068].
271 Onozawa M, Fukuhara T, Takahata M, et al. A case of myelodysplastic syndrome developed blastic crisis of chronic myelogenous leukemia with acquisition of major BCR/ABL. Annals of Hematology. 2003;82(9):593-595. [pmid: 12898186].
272 Ottmann OG, Wassmann B, Hoelzer D. Imatinib for relapsed BCR/ABL positive leukemias. Annals of Hematology. Suppl 2. 2002;81:S36-S37. [pmid: 12611069].
273 Piccaluga PP, Malagola M, Amabile M, et al. The achievement of molecular complete remission during treatment with imatinib mesylate correlates with relapse-free survival in bcr/abl-positive acute lymphoid leukemia patients. Haematologica. 2004;89(10):1269-1271. [pmid: 15477218].
274 Piccaluga PP, Malagola M, Rondoni M, et al. Dose increase of imatinib mesylate may overcome acquired resistance in bcr/abl-positive acute lymphoid leukaemia. European Journal of Haematology. 2004;72(4):302-303. [pmid: 15089772].
275 Potenza L, Luppi M, Riva G, et al. Efficacy of imatinib mesylate as maintenance therapy in adults with acute lymphoblastic leukemia in first complete remission. Haematologica. 2005;90(9):1275-1277. [pmid: 16154854].
276 Raanani P, Trakhtenbrot L, Rechavi G, et al. Philadelphia-chromosome-positive T-lymphoblastic leukemia: acute leukemia or chronic myelogenous leukemia blastic crisis. Acta Haematologica. 2005;113(3):181-189. [pmid: 15870488].
277 Sakai M, Ohashi K, Kobayashi T, et al. Cytogenetic abnormalities without evidence of relapse after treatment with imatinib and stem cell transplantation in a patient with Ph-positive ALL. International Journal of Hematology. 2005;81(2):171-173. [pmid: 15765789].
278 Sanchez-Gonzalez B, Pascual-Ramirez JC, Fernandez-Abellan P, et al. Severe skin reaction to imatinib in a case of Philadelphia-positive acute lymphoblastic leukemia. Blood. 2003;101(6):2446. [pmid: 12609964].
279 Savani BN, Srinivasan R, Espinoza-Delgado I, et al. Treatment of relapsed blast-phase Philadelphia-chromosome-positive leukaemia after non-myeloablative stem-cell transplantation with donor lymphocytes and imatinib. Lancet Oncology. 2005;6(10):809-812.
280 Scheuring UJ, Pfeifer H, Wassmann B, et al. Serial minimal residual disease (MRD) analysis as a predictor of response duration in Philadelphia-positive acute lymphoblastic leukemia (Ph+ALL) during imatinib treatment. Leukemia. 2003;17(9):1700-1706. [pmid: 12970767].
281 Shimoni A, Kroger N, Zander AR, et al. Imatinib mesylate (STI571) in preparation for allogeneic hematopoietic stem cell transplantation and donor lymphocyte infusions in patients with Philadelphia-positive acute leukemias. Leukemia. 2003;17(2):290-297. [pmid: 12592325].
282 Shin HJ, Chung JS, Cho GJ. Imatinib interim therapy between chemotherapeutic cycles and in vivo purging prior to autologous stem cell transplantation, followed by maintenance therapy is a feasible treatment strategy in Philadelphia chromosome-positive acute lymphoblastic leukemia. Bone Marrow Transplantation. 2005;36(10):917-918. [pmid: 16113662].
283 Stergianou K, Fox C, Russell NH. Fusion of NUP214 to ABL1 on amplified episomes in T-ALL--implications for treatment. Leukemia. 2005;19(9):1680-1681. [pmid: 16015385].
284 Sugimoto K, Mikoshiba M, Ohashi K, et al. Imatinib mesylate (Gleevec) in the treatment of 2 patients with Philadelphia-positive ALL relapsing after allogeneic stem cell transplantation. International Journal of Hematology. 2002;75(4):440-442. [pmid: 12041679].
285 Takami A, Shimadoi S, Sugimori C, et al. Successful treatment of minimal residual disease-positive Philadelphia chromosome-positive acute lymphoblastic leukemia with imatinib followed by reduced-intensity unrelated cord blood transplantation after allogeneic peripheral blood stem cell transplantation. International Journal of Hematology. 2006;84(2):170-173. [pmid: 16926141].
286 Takayama N, Sato N, O'Brien SG, et al. Imatinib mesylate has limited activity against the central nervous system involvement of Philadelphia chromosome-positive acute lymphoblastic leukaemia due to poor penetration into cerebrospinal fluid. British Journal of Haematology. 2002;119(1):106-108. [pmid: 12358909].
287 Visani G, Isidori A, Malagola M, et al. Efficacy of imatinib mesylate (STI571) in conjunction with alpha-interferon: long-term quantitative molecular remission in relapsed P-190(BCR-ABL)-positive acute lymphoblastic leukemia. Leukemia. 2002;16(10):2159-2160. [pmid: 12357372].
288 Wassmann B, Pfeifer H, Scheuring U, et al. Therapy with imatinib mesylate (Glivec) preceding allogeneic stem cell transplantation (SCT) in relapsed or refractory Philadelphia-positive acute lymphoblastic leukemia (Ph+ALL). Leukemia. 2002;16(12):2358-2365. [pmid: 12454740].
289 Wernstedt P, Brune M, Andersson PO, et al. Favorable outcome with STI571 (imatinib mesylate) and allogeneic stem cell transplantation in a case of Ph+ chemorefractory acute lymphocytic leukaemia. Bone Marrow Transplantation. 2002;30(12):971-973. [pmid: 12476293].
290 Metzgeroth G, Popp H, Walz C, et al. A phase-II study to evaluate efficacy and safety of Imatinib in eosinophilia-associated Myeloproliferative disorders and idiopathic hypereosinophilic syndrome. Blood. 2006;108(11). Abstract #671.
291 Mitra S, Murphy P, Thornton P. Hypereosinophilic Syndrome (HES)-variable presentation and response to current treatment options: Absence of the FIP1L1-PDGFRa fusion gene does not exclude Imatinib as a treatment option. Blood. 2006;108(25). Abstract #4922.
292 Rondoni M, Ottaviani E, Piccaluga P, et al. FIP1L1-PDGFRalpha positive hypereosinophilic syndrome (HES). The response to Imatinib (IM) is durable. A report of 21 patients with a follow-up of 12 to 67 months. Blood. 2006;108(11). Abstract #2700.
293 Rondoni M, Paolini S, Vigna E, et al. Systematic evaluation of hypereosinophilic syndrome-related organ damage according to FIP1L1=PDGFRA status and response to the therapy: Analysis from prospective clinical trial with Imatinib Mesylate. Blood. 2007;110(11). Abstract #3557.
294 Mitra S, Power D, Thornton P, et al. Hypereosinophilic syndromes (HESs) variable clinical presentations and responses to treatment. Journal of Clinical Oncology. 2007;25(18S). Abstract #17529.
295 Frickhofen N, Marker-Hermann E, Reiter A, et al. Complete molecular remission of chronic eosinophilic leukemia complicated by CNS disease after targeted therapy with imatinib. Annals of Hematology. 2004;83(7):477-480. [pmid: 14986065].
296 Ishii Y, Ito Y, Kuriyama Y, et al. Successful treatment with imatinib mesylate of hypereosinophilic syndrome (chronic eosinophilic leukemia) with myelofibrosis. Leukemia Research. Suppl 1. 2004;28:S79-S80. [pmid: 15036947].
297 Jovanovic JV, Score J, Waghorn K, et al. Low-dose imatinib mesylate leads to rapid induction of major molecular responses and achievement of complete molecular remission in FIP1L1-PDGFRA-positive chronic eosinophilic leukemia. Blood. 2007;109(11):4635-4640. [pmid: 17299092].
298 Kamineni P, Baptiste A, Hassan M, et al. Case of chronic eosinophilic leukemia with deletion of chromosome 16 and hepatitis C. Journal of the National Medical Association. 2006;98(8):1356-1360. [pmid: 16916138].
299 Malagola M, Martinelli G, Rondoni M, et al. Soft tissue and skeletal involvement in FIP1L1-PDGFR-alpha positive chronic eosinophilic leukemia: imatinib mesylate may induce complete molecular and imaging remission. Haematologica. 2004;89(8):ECR25. [pmid: 15339694].
300 Smith KJ, Jacobson E, Hamza S, et al. Unexplained hypereosinophilia and the need for cytogenetic and molecular genetic analyses. Archives of Dermatology. 2004;140(5):584-588. [pmid: 15148104].
301 Tanaka Y, Kurata M, Togami K, et al. Chronic eosinophilic leukemia with the FIP1L1-PDGFRalpha fusion gene in a patient with a history of combination chemotherapy. International Journal of Hematology. 2006;83(2):152-155. [pmid: 16513534].
302 Tashiro H, Shirasaki R, Noguchi M, et al. Molecular analysis of chronic eosinophilic leukemia with t(4;10) showing good response to imatinib mesylate. International Journal of Hematology. 2006;83(5):433-438. [pmid: 16787876].
303 Walz C, Curtis C, Schnittger S, et al. Transient response to imatinib in a chronic eosinophilic leukemia associated with ins(9;4)(q33;q12q25) and a CDK5RAP2-PDGFRA fusion gene. Genes, Chromosomes & Cancer. 2006;45(10):950-956. [pmid: 16845659].
304 Snow SN, Gordon EM, Larson PO, et al. Dermatofibrosarcoma protuberans: a report on 29 patients treated by Mohs micrographic surgery with long-term follow-up and review of the literature. Cancer. 2004;101(1):28-38. [pmid: 15221986].
305 Chen C-S, Siegel D. Dermatofibrosarcoma Protuberans. Available at: http://www.emedicine.com/derm/TOPIC97.HTM. 2007.
306 Criscione VD, Weinstock MA. Descriptive epidemiology of dermatofibrosarcoma protuberans in the United States, 1973 to 2002. Journal of the American Academy of Dermatology. 2007;56(6):968-973. [pmid: 17141362].
307 Chang CK, Jacobs IA, Salti GI. Outcomes of surgery for dermatofibrosarcoma protuberans. European Journal of Surgical Oncology. 2004;30(3):341-345. [pmid: 15028319].
308 McArthur G. Dermatofibrosarcoma protuberans: recent clinical progress. Annals of Surgical Oncology. 2007;14(10):2876-2886. [pmid: 17647063].
309 Shimizu A, O'Brien KP, Sjoblom T, et al. The dermatofibrosarcoma protuberans-associated collagen type Ialpha1/platelet-derived growth factor (PDGF) B-chain fusion gene generates a transforming protein that is processed to functional PDGF-BB. Cancer Research. 1999;59(15):3719-3723. [pmid: 10446987].
310 McArthur GA, Demetri GD, van Oosterom A, et al. Molecular and clinical analysis of locally advanced dermatofibrosarcoma protuberans treated with imatinib: Imatinib Target Exploration Consortium Study B2225. Journal of Clinical Oncology. 2005;23(4):866-873. [pmid: 15681532].
311 Lebbe C, Kerob D, Porcher R, et al. Imatinib mesylate as a preoperative therapy in dermatofibrosarcoma: Results of a multicentric phase II study on 25 patients. Journal of Clinical Oncology. 2007;25(18S). Abstract #10032.
312 Bigby SM, Oei P, Lambie NK, et al. Dermatofibrosarcoma protuberans: report of a case with a variant ring chromosome and metastases following pregnancy. Journal of Cutaneous Pathology. 2006;33(5):383-388. [pmid: 16640548].
313 Kasper B, Lossignol D, Gil T, et al. Imatinib mesylate in a patient with metastatic disease originating from a dermatofibrosarcoma protuberans of the scalp. Anti-Cancer Drugs. 2006;17(10):1223-1225. [pmid: 17075323].
314 Labropoulos SV, Fletcher JA, Oliveira AM, et al. Sustained complete remission of metastatic dermatofibrosarcoma protuberans with imatinib mesylate. Anti-Cancer Drugs. 2005;16(4):461-466. [pmid: 15746584].
315 Maki RG, Awan RA, Dixon RH, et al. Differential sensitivity to imatinib of 2 patients with metastatic sarcoma arising from dermatofibrosarcoma protuberans. International Journal of Cancer. 2002;100(6):623-626.
316 Mehrany K, Swanson NA, Heinrich MC, et al. Dermatofibrosarcoma protuberans: a partial response to imatinib therapy. Dermatologic Surgery. 2006;32(3):456-459. [pmid: 16640697].
317 Mizutani K, Tamada Y, Hara K, et al. Imatinib mesylate inhibits the growth of metastatic lung lesions in a patient with dermatofibrosarcoma protuberans. British Journal of Dermatology. 2004;151(1):235-237. [pmid: 15270901].
318 Price VE, Fletcher JA, Zielenska M, et al. Imatinib mesylate: an attractive alternative in young children with large, surgically challenging dermatofibrosarcoma protuberans. Pediatric Blood & Cancer. 2005;44(5):511-515. [pmid: 15503291].
319 Rubin BP, Schuetze SM, Eary JF, et al. Molecular targeting of platelet-derived growth factor B by imatinib mesylate in a patient with metastatic dermatofibrosarcoma protuberans. Journal of Clinical Oncology. 2002;20(17):3586-3591. [pmid: 12202658].
320 Savoia P, Ortoncelli M, Quaglino P, et al. Imatinib mesylate in the treatment of a large unresectable dermatofibrosarcoma protuberans: a case study. Dermatologic Surgery. 2006;32(8):1097-1102. [pmid: 16918576].
321 Wright TI, Petersen JE. Treatment of recurrent dermatofibrosarcoma protuberans with imatinib mesylate, followed by Mohs micrographic surgery. Dermatologic Surgery. 2007;33(6):741-744. [pmid: 17550456].
322 National Cancer Institute. Myelodysplastic syndromes treatment. Available at: http://www.cancer.gov/cancertopics/pdq/treatment/myelodysplastic. 2008.
323 Van Etten RA, Shannon KM. Focus on myeloproliferative diseases and myelodysplastic syndromes. Cancer Cell. 2004;6(6):547-552. [pmid: 15607959].
324 Besa E, Woerman U. Myelodysplastic syndrome. Available at: http://www.emedicine.com/med/TOPIC2695.HTM. 2008.
325 Greenberg P, Cox C, LeBeau MM, et al. International scoring system for evaluating prognosis in myelodysplastic syndromes. [erratum appears in Blood 1998 Feb 1;91(3):1100]. Blood. 1997;89(6):2079-2088. [pmid: 9058730].
326 Mufti G, List AF, Gore SD, et al. Myelodysplastic syndrome. Hematology. 2003:176-199. [pmid: 14633782].
327 Cortes J, Giles F, O'Brien S, et al. Results of imatinib mesylate therapy in patients with refractory or recurrent acute myeloid leukemia, high-risk myelodysplastic syndrome, and myeloproliferative disorders. Cancer. 2003;97(11):2760-2766. [pmid: 12767088].
328 Heidel F, Cortes J, Rucker FG, et al. Results of a multicenter phase II trial for older patients with c-Kit-positive acute myeloid leukemia (AML) and high-risk myelodysplastic syndrome (HR-MDS) using low-dose Ara-C and Imatinib. Cancer. 2007;109(5):907-914. [pmid: 17285599].
329 Drummond MW, Lush CJ, Vickers MA, et al. Imatinib mesylate-induced molecular remission of Philadelphia chromosome-positive myelodysplastic syndrome. Leukemia. 2003;17(2):463-465. [pmid: 12592349].
330 Mesa RA, Steensma DP, Hoyer J, et al. Concomitant myelodysplastic syndrome and chronic myeloid leukaemia: treatment outcomes with imatinib mesylate. British Journal of Haematology. 2003;123(2):366-367. [pmid: 14531922].
331 Krishnan K, Ramu V, Krishnaswamy G, et al. Mastocytosis, Systemic. Available at: http://www.emedicine.com/med/TOPIC1401.HTM. 2006.
332 Escribano L, Akin C, Castells M, et al. Mastocytosis: current concepts in diagnosis and treatment. Annals of Hematology. 2002;81(12):677-690. [pmid: 12483363].
333 Kluin-Nelemans HC, Oldhoff JM, Van Doormaal JJ, et al. Cladribine therapy for systemic mastocytosis. Blood. 2003;102(13):4270-4276. [pmid: 12933573].
334 Alto WA, Clarcq L. Cutaneous and systemic manifestations of mastocytosis. American Family Physician. 1999;59(11):3047-3054. [pmid: 10392589].
335 Patnaik MM, Rindos M, Kouides PA, et al. Systemic mastocytosis: a concise clinical and laboratory review. Archives of Pathology & Laboratory Medicine. 2007;131(5):784-791. [pmid: 17488167].
336 Pardanani A, Ketterling RP, Brockman SR, et al. CHIC2 deletion, a surrogate for FIP1L1-PDGFRA fusion, occurs in systemic mastocytosis associated with eosinophilia and predicts response to imatinib mesylate therapy. Blood. 2003;102(9):3093-3096. [pmid: 12842979].
337 Droogendijk HJ, Kluin-Nelemans HJC, van Doormaal JJ, et al. Imatinib mesylate in the treatment of systemic mastocytosis: a phase II trial. Cancer. 2006;107(2):345-351. [pmid: 16779792].
338 Pardanani A, Elliott M, Reeder T, et al. Imatinib for systemic mast-cell disease. Lancet. 2003;362(9383):535-536. [pmid: 12932387].
339 Hsieh F, Lichtin A, Katz H, et al. Imatinib Mesylate in the treatment of systemic mastocytosis with wild-type c-Kit Codon 816. Blood. 2006;108(11). Abstract #4926.
340 Pagano L, Valentini C, Musto P, et al. Systemic Mastocytosis. A GIMEMA Multicenter Survey. Blood. 2006;108(11). Abstract #4874.
341 Sohal G, Hammour T, Chamarthy U, et al. Mast cell sarcoma presenting as a spinal cord tumor. Blood. 2006;108(11). Abstract #4451.
342 Akin C, Fumo G, Yavuz AS, et al. A novel form of mastocytosis associated with a transmembrane c-kit mutation and response to imatinib. Blood. 2004;103(8):3222-3225. [pmid: 15070706].
343 Callera F, Chauffaille MdLLF. Aggressive systemic mastocytosis: is there a role for trisomy 8?. Leukemia Research. 2005;29(4):471-473. [pmid: 15725484].
344 Dalal BI, Horsman DE, Bruyere H, et al. Imatinib mesylate responsiveness in aggressive systemic mastocytosis: novel association with a platelet derived growth factor receptor beta mutation. American Journal of Hematology. 2007;82(1):77-79. [pmid: 17133421].
345 Elliott MA, Pardanani A, Li CY, et al. Immunophenotypic normalization of aberrant mast cells accompanies histological remission in imatinib-treated patients with eosinophilia-associated mastocytosis. Leukemia. 2004;18(5):1027-1029. [pmid: 15014525].
346 Florian S, Esterbauer H, Binder T, et al. Systemic mastocytosis (SM) associated with chronic eosinophilic leukemia (SM-CEL): detection of FIP1L1/PDGFRalpha, classification by WHO criteria, and response to therapy with imatinib. Leukemia Research. 2006;30(9):1201-1205. [pmid: 16406018].
347 Hennessy B, Giles F, Cortes J, et al. Management of patients with systemic mastocytosis: review of M.D. Anderson Cancer Center experience. American Journal of Hematology. 2004;77(3):209-214. [pmid: 15495258].
348 Merante S, Chichino G, Boveri E, et al. First case of an AIDS patient with systemic mast cell disease associated with FIP1-positive eosinophilia treated with imatinib mesylate therapy. Journal of Clinical Oncology. 2006;24(4):e6-e7. [pmid: 16446324].
349 Musto P, Falcone A, Sanpaolo G, et al. Inefficacy of imatinib-mesylate in sporadic, aggressive systemic mastocytosis. Leukemia Research. 2004;28(4):421-422. [pmid: 15109544].
350 U.S. Food and Drug Administration. FDA Alert on rituximab (marketed as Rituxan). December. 2006. Available at: www.fda.gov/CDER/Drug/InfoSheets/HCP/rituximab.pdf. Accessed 17 October 2008.
351 American Cancer Society. Cancer facts and figures 2008. Available at: http://www.cancer.org/docroot/STT/content/STT_1x_Cancer_Facts_and_Figures_2008.asp. 2008.
352 DiGiuseppe JA, Borowitz MJ. Clinical utility of flow cytometry in the chronic lymphoid leukemias. Seminars in Oncology. 1998;25(1):6-10. [pmid: 9482521].
353 Binet J-L, Caligaris-Cappio F, Catovsky D, et al. Perspectives on the use of new diagnostic tools in the treatment of chronic lymphocytic leukemia. Blood. 2006;107(3):859-861. [pmid: 16223776].
354 National Cancer Institute. Chronic lymphocytic leukemia treatment. Available at: http://www.cancer.gov/cancertopics/pdq/treatment/CLL/healthprofessional/allpages#Reference4.2. 2008.
355 Perry M, Rasool H. Chronic lymphocytic leukemia. Available at: http://www.emedicine.com/med/topic370.htm. 2005.
356 Chiorazzi N, Rai KR, Ferrarini M. Chronic lymphocytic leukemia. New England Journal of Medicine. 2005;352(8):804-815. [pmid: 15728813].
357 Faguet GB. Chronic lymphocytic leukemia: an updated review. Journal of Clinical Oncology. 1994;12(9):1974-1990. [pmid: 8083719].
358 Montserrat E. Current and developing chemotherapy for CLL. Medical Oncology. Suppl. 2002;19:S11-S19. [pmid: 12180487].
359 Winkler U, Jensen M, Manzke O, et al. Cytokine-release syndrome in patients with B-cell chronic lymphocytic leukemia and high lymphocyte counts after treatment with an anti-CD20 monoclonal antibody (rituximab, IDEC-C2B8). Blood. 1999;94(7):2217-2224. [pmid: 10498591].
360 Jensen M, Winkler U, Manzke O, et al. Rapid tumor lysis in a patient with B-cell chronic lymphocytic leukemia and lymphocytosis treated with an anti-CD20 monoclonal antibody (IDEC-C2B8, rituximab). Annals of Hematology. 1998;77(1–2):89-91. [pmid: 9760161].
361 Byrd JC, Murphy T, Howard RS, et al. Rituximab using a thrice weekly dosing schedule in B-cell chronic lymphocytic leukemia and small lymphocytic lymphoma demonstrates clinical activity and acceptable toxicity. Journal of Clinical Oncology. 2001;19(8):2153-2164. [pmid: 11304767].
362 Bannerji R, Kitada S, Flinn IW, et al. Apoptotic-regulatory and complement-protecting protein expression in chronic lymphocytic leukemia: relationship to in vivo rituximab resistance. Journal of Clinical Oncology. 2003;21(8):1466-1471. [pmid: 12697868].
363 Byrd JC, Smith L, Hackbarth ML, et al. Interphase cytogenetic abnormalities in chronic lymphocytic leukemia may predict response to rituximab. Cancer Research. 2003;63(1):36-38. [pmid: 12517774].
364 Farag SS, Flinn IW, Modali R, et al. Fc gamma RIIIa and Fc gamma RIIa polymorphisms do not predict response to rituximab in B-cell chronic lymphocytic leukemia. Blood. 2004;103(4):1472-1474. [pmid: 14563637].
365 Del Poeta G, Del Principe MI, Consalvo MAI, et al. The addition of rituximab to fludarabine improves clinical outcome in untreated patients with ZAP-70-negative chronic lymphocytic leukemia. Cancer. 2005;104(12):2743-2752. [pmid: 16284990].
366 Hainsworth JD, Litchy S, Barton JH, et al. Single-agent rituximab as first-line and maintenance treatment for patients with chronic lymphocytic leukemia or small lymphocytic lymphoma: a phase II trial of the Minnie Pearl Cancer Research Network. Journal of Clinical Oncology. 2003;21(9):1746-1751. [pmid: 12721250].
367 Itala M, Geisler CH, Kimby E, et al. Standard-dose anti-CD20 antibody rituximab has efficacy in chronic lymphocytic leukaemia: results from a Nordic multicentre study. European Journal of Haematology. 2002;69(3):129-134. [pmid: 12406005].
368 Kay NE, Geyer SM, Call TG, et al. Combination chemoimmunotherapy with pentostatin, cyclophosphamide, and rituximab shows significant clinical activity with low accompanying toxicity in previously untreated B chronic lymphocytic leukemia. Blood. 2007;109(2):405-411. [pmid: 17008537].
369 Shanafelt TD, Lin T, Geyer SM, et al. Pentostatin, cyclophosphamide, and rituximab regimen in older patients with chronic lymphocytic leukemia. Cancer. 2007;109(11):2291-2298. [pmid: 17514743].
370 Keating MJ, O'Brien S, Albitar M, et al. Early results of a chemoimmunotherapy regimen of fludarabine, cyclophosphamide, and rituximab as initial therapy for chronic lymphocytic leukemia. Journal of Clinical Oncology. 2005;23(18):4079-4088. [pmid: 15767648].
371 Khouri IF, Lee M-S, Saliba RM, et al. Nonablative allogeneic stem cell transplantation for chronic lymphocytic leukemia: impact of rituximab on immunomodulation and survival. Experimental Hematology. 2004;32(1):28-35. [pmid: 14725898].
372 Lamanna N, Kalaycio M, Maslak P, et al. Pentostatin, cyclophosphamide, and rituximab is an active, well-tolerated regimen for patients with previously treated chronic lymphocytic leukemia. Journal of Clinical Oncology. 2006;24(10):1575-1581. [pmid: 16520464].
373 Robak T, Smolewski P, Cebula B, et al. Rituximab plus cladribine with or without cyclophosphamide in patients with relapsed or refractory chronic lymphocytic leukemia. European Journal of Haematology. 2007;79(2):107-113. [pmid: 17635235].
374 Savage DG, Cohen NS, Hesdorffer CS, et al. Combined fludarabine and rituximab for low grade lymphoma and chronic lymphocytic leukemia. Leukemia & Lymphoma. 2003;44(3):477-481. [pmid: 12688318].
375 Schulz H, Klein SK, Rehwald U, et al. Phase 2 study of a combined immunochemotherapy using rituximab and fludarabine in patients with chronic lymphocytic leukemia. Blood. 2002;100(9):3115-3120. [pmid: 12384407].
376 Tam CS, Wolf M, Prince HM, et al. Fludarabine, cyclophosphamide, and rituximab for the treatment of patients with chronic lymphocytic leukemia or indolent non-Hodgkin lymphoma. Cancer. 2006;106(11):2412-2420. [pmid: 16649223].
377 Tsiara SN, Kapsali HD, Chaidos A, et al. Treatment of resistant/relapsing chronic lymphocytic leukemia with a combination regimen containing deoxycoformycin and rituximab. Acta Haematologica. 2004;111(4):185-188. [pmid: 15153709].
378 Tsimberidou AM, Kantarjian HM, Cortes J, et al. Fractionated cyclophosphamide, vincristine, liposomal daunorubicin, and dexamethasone plus rituximab and granulocyte-macrophage-colony stimulating factor (GM-CSF) alternating with methotrexate and cytarabine plus rituximab and GM-CSF in patients with Richter syndrome or fludarabine-refractory chronic lymphocytic leukemia. Cancer. 2003;97(7):1711-1720. [pmid: 12655528].
379 Weide R, Pandorf A, Heymanns J, et al. Bendamustine/Mitoxantrone/Rituximab (BMR): a very effective, well tolerated outpatient chemoimmunotherapy for relapsed and refractory CD20-positive indolent malignancies. Final results of a pilot study. Leukemia & Lymphoma. 2004;45(12):2445-2449. [pmid: 15621757].
380 Weide R, Heymanns J, Gores A, et al. Bendamustine mitoxantrone and rituximab (BMR): a new effective regimen for refractory or relapsed indolent lymphomas. Leukemia & Lymphoma. 2002;43(2):327-331. [pmid: 11999564].
381 Wierda W, O'Brien S, Wen S, et al. Chemoimmunotherapy with fludarabine, cyclophosphamide, and rituximab for relapsed and refractory chronic lymphocytic leukemia. Journal of Clinical Oncology. 2005;23(18):4070-4078. [pmid: 15767647].
382 Wierda W, O'Brien S, Faderl S, et al. A retrospective comparison of three sequential groups of patients with Recurrent/Refractory chronic lymphocytic leukemia treated with fludarabine-based regimens. Cancer. 2006;106(2):337-345. [pmid: 16353201].
383 Del Poeta G, Del Principe M, Maurillo L, et al. Consolidation and maintenance immunotherapy with rituximab improve progression free survival within ZAP-70 positive chronic lymphocytic leukemia (CLL). Blood. 2006;108(11). Abstract #2824.
384 Faderl S, Ferrajoli A, Wierda W, et al. The combination of alemtuzumab [continuous intravenous (civ) followed by subcutaneous injection (sc)] plus rituximab has activity in patients (pts) with relapsed chronic lymphocytic leukemia (CLL). Blood. 2006;108(11). Abstract #2827.
385 Faderl S, Wierda W, O'Brien S, et al. Fludarabine, cyclophosphamide, mitoxantrone plus rituximab (FCM-R) as frontline therapy for SLL: Results of a Phase II study. Blood. 2006;108(11). Abstract #2836.
386 Kay N, Geyer S, Call T, et al. Combination chemotherapy with pentostatin, cyclophosphamide and rituximab shows significant clinical activity with low accompanying toxicity in previously untreated B-Chronic Lymphocytic Leukemia. Blood. 2006;108(11). Abstract #35.
387 Klepfish A, Schattner A, Kotsianidis J. Addition of fresh frozen plasma to rituximab indices a major clinical and laboratory response in patients with refractory advanced CLL. Blood. 2006;108(11). Abstract #4986.
388 Lin T, Lucas M, Heerema N, et al. A phase II study of the TNF-alpha inhibitor etanercept and thrice weekly rituximab in relapsed CLL/SLL: Clinical activity in the absence of Del(17p13) genomic abnormailities. Blood. 2006;108(11). Abstract #2841.
389 Mena R, Robles R, Auerbach M, et al. A multi-center, open-label study to evaluate the safety and efficacy of pentostatin, cytoxan, and rituxan (PCR) in the treatment of previously untreated or treated, stage II, III, or IV CLL. Blood. 2006;108(11). Abstract #4978.
390 Pavlovsky C, Pavlovsky S, Pardo M, et al. Therapy with fludarabine, cyclophosphamide and rituximab (FCR) for relapsed or untreated progressive Chronic Lymphocytic Leukemia (CLL). A single center experience. Blood. 2006;108(11). Abstract #4968.
391 Tam C, Wen S, Do K-A, et al. The effect of initial therapy choice in determining long term survival in patients with chronic lymphocytic leukemia (CLL). Blood. 2006;108(11). Abstract #4976.
392 Tarhini A, Land S, Meisner D, et al. Early clinical and pharmabokinetic results of lower dose fludarabine and cyclophosphamide, and high dose rituximab (FCR-Lite) for patients with untreated chronic lymphocytic leukemia (CLL). Blood. 2006;108(11). Abstract #2844.
393 Tsimberidou A-M, Wierda W, O'Brien S, et al. Combination of oxaliplatin, fludarabine, cytarabine, and rituximab in Richter's syndrome and fludarabine-refractory Chronic Lymphocytic Leukemia. Blood. 2006;108(11). Abstract #2825.
394 Wierda W, O'Brien S, Faderl S, et al. Combined cyclophosphamide, fludarabine, alemtuzumab, and rituximab (CFAR), an active regimen for heavily treated patients with CLL. Blood. 2006;108(11). Abstract #31.
395 Zent C, Bone N, Call T, et al. Alemtuzumab and rituximab for therapy of patients with early stage high risk CLL: Report of a planned interim analysis. Blood. 2006;108(11). Abstract #2829.
396 Bosch F, Muntanola A, Villamor N, et al. Preliminary results of the combination rituximab, fludarabine, cyclophosphamide and mitoxantrone (R-FCM) followed by rituximab maintenance in previously untreated chronic lymphocytic leukemia (CLL). Blood. 2007;110(11). Abstract #626.
397 Del Poeta G, Del Principe M, Maurillo L, et al. Rituximab consolidation and maintenance immunotherapy improve outcome in B-cell Chronic Lymphocytic Leukemia. Blood. 2007;110(11). Abstract #2035.
398 Dungarwalla M, Kanagasabapathy P, Kulkarni S, et al. High dose Methylprednisolone and Rituximab is an effective therapy in advanced refractory Chronic Lymphocytic Leukemia resistant to Fludarabine therapy. Blood. 2007;110(11). Abstract #3125.
399 Egle A, Weiss L, Russ G, et al. Planned first efficacy and safety analysis of de-intensified induction with fludarabine, cyclophosphamide plus rituximab (FCR) followed by fludarabine plus rituximab (FR) and remission maintenance therapy with rituximab in previously untreated B-chronic lymphocytic leukemia (B-CLL): The Chairos study. Blood. 2007;110(11). Abstract #2045.
400 Faderl S, Wierda W, Ferrajoli A, et al. Update of experience with Fludarabine, Cyclophosphamide, Mitoxantrone plus Rituximab (FCM-R) in frontline therapy for Chronic Lymphocytic Leukemia (CLL). Blood. 2007;110(11). Abstract #627.
401 Frankfurt O, Hamilton E, Acharya S, et al. A phase II trial of Alemtuzumab and Rituximab in patients with previously untreated CLL. Blood. 2007;110(11). Abstract #2056.
402 Hillmen P, Pocock C, Cohen D, et al. Trial: A randomized phase II trial of Fludarabine, Cyclophosphamide and Mitoxantrone (FCM) with or without Rituximab in previously treated CLL. Blood. 2007;110(11). Abstract #752.
403 Kempin S, Kay N, Sun Z, et al. Early results of Pentostatin, Cytoxan, Rituximab (PCR) followed by CAMPATH-H (CA) for the treatment of relapse/refractory Chronic Lymphocytic Leukemia (CLL) in ECOG Protocol E2903. Blood. 2007;110(11). Abstract #3109.
404 Lamanna N, Heaney M, Brentjens R, et al. Pentostatin, Cyclophosphamide, Rituximab, and Mitoxantrone (PCRM): A new highly active regimen for patients with Chronic Lymphocytic Leukemia (CLL) previously treated with PCR or FCR. Blood. 2007;110(11). Abstract #3115.
405 Leupin N, Schuller J, Solenthaler M, et al. The combination of 2-CDA and Rituximab in patients with Chronic Lymphocytic Leukemia (CLL): A prospective multicenter phase II trial (SAKK 34/02). Blood. 2007;110(11). Abstract #2057.
406 Mena R, Moezi M, Robles R. A multi-center, open-label study to evaluate the safety and efficacy of Pentostatin, Cytoxan, and Rituxan (PCR) in the treatment of previously untreated or treated, stage, II, III or IV Chronic Lymphocytic Leukemia (CLL). Blood. 2007;110(11). Abstract #1356.
407 Moffa C, Thatikonda C, Pathe N, et al. A retrospective analysis of response to high dose Rituximab monotherapy in CLL/NHL patients who received prior standard dose Rituximab therapy. Blood. 2007;110(11). Abstract #4722.
408 Quinn J, Mohamedbhai S, Treacey M, et al. Rituximab in combination with high-dose steroids in advanced, refractory Chronic Lymphocytic Leukemia. Blood. 2007;110(11). Abstract #4719.
409 Rieger M, Witzens-Harig M, Hensel M, et al. Rituximab improves the outcome of upfront autologous stem cell transplantation in mantle cell lymphoma: A comparison of different strategies. Blood. 2007;110(11). Abstract #5106.
410 Tarhini A, Land S, Pietragallo L, et al. Final results of lower dose Fludarabine (F) and Cyclophosphamide (C), and high dose Rituximab (R), (FCR-Lite) for patients with untreated Chronic Lymphocytic Leukemia (CLL). Blood. 2007;110(11). Abstract #2037.
411 Wierda W, O'Brien S, Ferrajoli A, et al. Combined Cyclophosphamide, Fludarabine, Alemtuzumab, and Rituximab (CFAR), an active frontline regimen for high-risk patients with CLL. Blood. 2007;110(11). Abstract # 628.
412 Zent C, Call T, Shanafelt T, et al. Alemtuzumab and Rituximab for initial treatment of high risk, early stage Chronic Lymphocytic Leukemia (CLL). Blood. 2007;110(11). Abstract #2050.
413 Mena R, Robles R, Auerbach M, et al. A multi-center, open-label study to evaluate the safety and efficacy of pentostatin, cytoxan, and rituxan (PCR) in the treatment of previously untreated or treated, stage III or IV, low-grade CLL. Journal of Clinical Oncology. 2007;25(18S). Abstract #17508.
414 Tam C, O'Brien S, Wierda W, et al. Seventy percent of complete responders remain in continuous remission: Five-year follow-up of 300 patients treated with fludarabine, cyclophosphamide, and rituximab (FCR) as initial therapy of CLL. Journal of Clinical Oncology. 2007;25(18S). Abstract #7008.
415 Berkahn L, Simpson D, Raptis A, et al. In vivo purging with rituximab prior to collection of stem cells for autologous transplantation in chronic lymphocytic leukemia. Journal of Hematotherapy & Stem Cell Research. 2002;11(2):315-320. [pmid: 11983102].
416 Borthakur G, O'Brien S, Wierda WG, et al. Immune anaemias in patients with chronic lymphocytic leukaemia treated with fludarabine, cyclophosphamide and rituximab--incidence and predictors. British Journal of Haematology. 2007;136(6):800-805. [pmid: 17341265].
417 Byrd JC, Gribben JG, Peterson BL, et al. Select high-risk genetic features predict earlier progression following chemoimmunotherapy with fludarabine and rituximab in chronic lymphocytic leukemia: justification for risk-adapted therapy. Journal of Clinical Oncology. 2006;24(3):437-443. [pmid: 16344317].
418 Byrd JC, Rai K, Peterson BL, et al. Addition of rituximab to fludarabine may prolong progression-free survival and overall survival in patients with previously untreated chronic lymphocytic leukemia: an updated retrospective comparative analysis of CALGB 9712 and CALGB 9011. Blood. 2005;105(1):49-53. [pmid: 15138165].
419 Byrd JC, Waselenko JK, Maneatis TJ, et al. Rituximab therapy in hematologic malignancy patients with circulating blood tumor cells: association with increased infusion-related side effects and rapid blood tumor clearance. Journal of Clinical Oncology. 1999;17(3):791-795. [pmid: 10071268].
420 Cohen Y, Da'as N, Libster D, et al. Large-cell transformation of chronic lymphocytic leukemia and follicular lymphoma during or soon after treatment with fludarabine-rituximab-containing regimens: natural history- or therapy-related complication?. European Journal of Haematology. 2002;68(2):80-83. [pmid: 12038452].
421 Dereure O, Navarro R, Rossi JF, et al. Rituximab-induced vasculitis. Dermatology. 2001;203(1):83-84. [pmid: 11549810].
422 Garypidou V, Perifanis V, Tziomalos K, et al. Cardiac toxicity during rituximab administration. Leukemia & Lymphoma. 2004;45(1):203-204. [pmid: 15061224].
423 Harrer T, Geissdorfer W, Schoerner C, et al. Seronegative Lyme neuroborreliosis in a patient on treatment for chronic lymphatic leukemia. Infection. 2007;35(2):110-113. [pmid: 17401717].
424 Herold M, Schulze A, Hartwig K, et al. Successful treatment and re-treatment of resistant B-cell chronic lymphocytic leukemia with the monoclonal anti-CD 20 antibody rituximab. Annals of Hematology. 2000;79(6):332-335. [pmid: 10901614].
425 Jourdan E, Topart D, Richard B, et al. Severe autoimmune hemolytic anemia following rituximab therapy in a patient with a lymphoproliferative disorder. Leukemia & Lymphoma. 2003;44(5):889-890. [pmid: 12802933].
426 Kanelli S, Ansell SM, Habermann TM, et al. Rituximab toxicity in patients with peripheral blood malignant B-cell lymphocytosis. Leukemia & Lymphoma. 2001;42(6):1329-1337. [pmid: 11911416].
427 Klepfish A, Schattner A, Ghoti H, et al. Addition of fresh frozen plasma as a source of complement to rituximab in advanced chronic lymphocytic leukaemia. Lancet Oncology. 2007;8(4):361-362.
428 Kunzmann V, Ruediger T, Hallek M, et al. Tumor cell agglutination and not solely cytokine release as mechanism of adverse reactions during anti-CD20 monoclonal antibody (IDEC-C2B8, rituximab) treatment. Blood. 2001;98(6):1991-1992. [pmid: 11565541].
429 Ladetto M, Bergui L, Ricca I, et al. Rituximab anti-CD20 monoclonal antibody induces marked but transient reductions of peripheral blood lymphocytes in chronic lymphocytic leukaemia patients. Medical Oncology. 2000;17(3):203-210. [pmid: 10962531].
430 Lim LC, Koh LP, Tan P. Fatal cytokine release syndrome with chimeric anti-CD20 monoclonal antibody rituximab in a 71-year-old patient with chronic lymphocytic leukemia. Journal of Clinical Oncology. 1999;17(6):1962-1963. [pmid: 10561242].
431 Nabhan C, Patton D, Gordon LI, et al. A pilot trial of rituximab and alemtuzumab combination therapy in patients with relapsed and/or refractory chronic lymphocytic leukemia (CLL). Leukemia & Lymphoma. 2004;45(11):2269-2273. [pmid: 15512816].
432 Narayan H, Bandyopadhyay D, Schmidt K, et al. Successful treatment of a patient with chronic lymphocytic leukaemia (CLL) presenting with bony metastases with aggressive antibody and chemotherapy. Clinical & Laboratory Haematology. 2005;27(6):405-408. [pmid: 16307545].
433 Nieto Y, Bearman SI, Shpall EJ, et al. Intensive chemotherapy for progressive chronic lymphocytic leukemia administered early after a nonmyeloablative allograft. Bone Marrow Transplantation. 2001;28(11):1083-1086. [pmid: 11781620].
434 Niscola P, Del Principe MI, Maurillo L, et al. Fulminant B hepatitis in a surface antigen-negative patient with B-cell chronic lymphocytic leukaemia after rituximab therapy. Leukemia. 2005;19(10):1840-1841. [pmid: 16094417].
435 O'Brien SM, Kantarjian H, Thomas DA, et al. Rituximab dose-escalation trial in chronic lymphocytic leukemia. Journal of Clinical Oncology. 2001;19(8):2165-2170. [pmid: 11304768].
436 Robak T, Gora-Tybor J, Tybor K, et al. Richter's syndrome in the brain first manifested as an ischaemic stroke. Leukemia & Lymphoma. 2004;45(6):1261-1267. [pmid: 15360010].
437 Sarrecchia C, Cappelli A, Aiello P. HBV reactivation with fatal fulminating hepatitis during rituximab treatment in a subject negative for HBsAg and positive for HBsAb and HBcAb. Journal of Infection & Chemotherapy. 2005;11(4):189-191. [pmid: 16133710].
438 Scaramucci L, Niscola P, Buffolino S, et al. Repeated rituximab maintenance courses in fludarabine-failed young patients with chronic lymphocytic leukaemia responding to FAND chemotherapy. Hematology Journal. 2004;5(2):186-187. [pmid: 15048071].
439 Sokol L, Agosti SJ. Simultaneous manifestation of chronic lymphocytic leukemia (CLL) and hairy cell leukemia (HCL). American Journal of Hematology. 2004;75(2):107-109. [pmid: 14755378].
440 Tinhofer I, Steurer M, Leitinger G, et al. The effect of IgVH mutational status on the induction of apoptosis by rituximab in patients with heavily pretreated B-cell chronic lymphocytic leukemia: evidence from a clinical phase I/II trial. Haematologica. 2006;91(9):1291-1293. [pmid: 16956841].
441 Voog E, Morschhauser F, Solal-Celigny P. Neutropenia in patients treated with rituximab. New England Journal of Medicine. 2003;348(26):2691-2694. discussion 2691-4. [pmid: 12826650].
442 Watanabe N, Takahashi T, Sugimoto N, et al. Excellent response of chemotherapy-resistant B-cell-type chronic lymphocytic leukemia with meningeal involvement to rituximab. International Journal of Clinical Oncology. 2005;10(5):357-361. [pmid: 16247665].
443 Williams ME, Densmore JJ, Pawluczkowycz AW, et al. Thrice-weekly low-dose rituximab decreases CD20 loss via shaving and promotes enhanced targeting in chronic lymphocytic leukemia. Journal of Immunology. 2006;177(10):7435-7443.
444 Yang H, Rosove MH, Figlin RA. Tumor lysis syndrome occurring after the administration of rituximab in lymphoproliferative disorders: high-grade non-Hodgkin's lymphoma and chronic lymphocytic leukemia. American Journal of Hematology. 1999;62(4):247-250. [pmid: 10589082].
445 Hainsworth JD, Litchy S, Burris HA 3rd, et al. Rituximab as first-line and maintenance therapy for patients with indolent non-hodgkin's lymphoma. Journal of Clinical Oncology. 2002;20(20):4261-4267. [pmid: 12377971].
446 Ekstrand BC, Horning SJ. Lymphocyte predominant Hodgkin's disease. Current Oncology Reports. 2002;4(5):424-433. [pmid: 12162918].
447 Diehl V, Sextro M, Franklin J, et al. Clinical presentation, course, and prognostic factors in lymphocyte-predominant Hodgkin's disease and lymphocyte-rich classical Hodgkin's disease: report from the European Task Force on Lymphoma Project on Lymphocyte-Predominant Hodgkin's Disease. Journal of Clinical Oncology. 1999;17(3):776-783. [pmid: 10071266].
448 Aster JC. Lymphocyte-predominant Hodgkin's disease: how little therapy is enough?. Journal of Clinical Oncology. 1999;17(3):744-746. [pmid: 10071261].
449 Dores GM, Metayer C, Curtis RE, et al. Second malignant neoplasms among long-term survivors of Hodgkin's disease: a population-based evaluation over 25 years. Journal of Clinical Oncology. 2002;20(16):3484-3494. [pmid: 12177110].
450 Rehwald U, Schulz H, Reiser M, et al. Treatment of relapsed CD20+ Hodgkin lymphoma with the monoclonal antibody rituximab is effective and well tolerated: results of a phase 2 trial of the German Hodgkin Lymphoma Study Group. Blood. 2003;101(2):420-424. [pmid: 12509381].
451 Henry-Amar M. Second cancer after the treatment for Hodgkin's disease: a report from the International Database on Hodgkin's Disease. Annals of Oncology. Suppl 4. 1992;3:117-128. [pmid: 1450072].
452 Lush RJ, Jones SG, Haynes AP. Advanced-stage, chemorefractory lymphocyte-predominant Hodgkin's disease: long-term follow-up of allografting and monoclonal antibody therapy. British Journal of Haematology. 2001;114(3):734-735. [pmid: 11553009].
453 Ekstrand BC, Lucas JB, Horwitz SM, et al. Rituximab in lymphocyte-predominant Hodgkin disease: results of a phase 2 trial. Blood. 2003;101(11):4285-4289. [pmid: 12586628].
454 Genadieva-Stavrik S, Ivkovski L, Pivkova A. Initial treatment of CD20+ lymphocyte predominant Hodgkin Lymphoma with chemotherapy and the monoclonal antibody retuximab-mabthera is effective and well tolerated - Case Report. Blood. 2006;108(11). Abstract #4696.
455 Horning S, Bartlett N, Breslin S, et al. Results of a prospective phase II trial of limited and extended rituximab treatment of nodular lymphocyte predominant Hodgkin's disease (NLPHD). Blood. 2007;110(11). Abstract #644.
456 Boulanger E, Meignin V, Leverger G, et al. Rituximab monotherapy in nodular lymphocyte-predominant Hodgkin's disease. Annals of Oncology. 2003;14(1):171. [pmid: 12488312].
457 Culi S, Armanda V, Kuljis D, et al. Anti-CD20 monoclonal antibody (rituximab) for therapy of CD20-positive nodular lymphocyte-predominant Hodgkin lymphoma in an 10-year-old girl. Pediatric Hematology & Oncology. 2006;23(8):661-666. [pmid: 17065142].
458 Ibom VK, Prosnitz RG, Gong JZ, et al. Rituximab in lymphocyte predominance Hodgkin's disease: a case series. Clinical Lymphoma. 2003;4(2):115-118. [pmid: 14556684].
459 Keilholz U, Szelenyi H, Siehl J, et al. Rapid regression of chemotherapy refractory lymphocyte predominant Hodgkin's disease after administration of rituximab (anti CD 20 mono- clonal antibody) and interleukin-2. Leukemia & Lymphoma. 1999;35(5–6):641-642. [pmid: 10609806].
460 Rose AL, Forsythe AM, Maloney DG. Agranulocytosis unresponsive to growth factors following rituximab in vivo purging. Blood. 2003;101(10):4225-4226. [pmid: 12732505].
461 Unal A, Sari I, Deniz K, et al. Familial nodular lymphocyte predominant Hodgkin lymphoma: Successful treatment with CHOP plus rituximab. Leukemia & Lymphoma. 2005;46(11):1613-1617. [pmid: 16236615].
462 National Cancer Institute. Waldenstrom macroglobulinemia: Questions and Answers. Available at: http://www.cancer.gov/cancertopics/factsheet/Sites-Types/WM. 2007.
463 American Cancer Society. Detailed Guide: Waldenstrom macroglobulinemia. Available at: http://documents.cancer.org/162.00/162.00.pdf. 2008.
464 Dimopoulos MA, Alexanian R, Gika D, et al. Treatment of Waldenstrom's macroglobulinemia with rituximab: prognostic factors for response and progression. Leukemia & Lymphoma. 2004;45(10):2057-2061. [pmid: 15370250].
465 Dimopoulos MA, Merlini G, Leblond V, et al. How we treat Waldenstrom's macroglobulinemia. Haematologica. 2005;90(1):117-125. [pmid: 15642678].
466 Byrd JC, White CA, Link B, et al. Rituximab therapy in Waldenstrom's macroglobulinemia: preliminary evidence of clinical activity. Annals of Oncology. 1999;10(12):1525-1527. [pmid: 10643548].
467 Weide R, Heymanns J, Koppler H. Induction of complete haematological remission after monotherapy with anti-CD20 monoclonal antibody (RITUXIMAB) in a patient with alkylating agent resistant Waldenstrom's macroglobulinaemia. Leukemia & Lymphoma. 1999;36(1–2):203-206. [pmid: 10613467].
468 Dimopoulos MA, Anagnostopoulos A, Zervas C, et al. Predictive factors for response to rituximab in Waldenstrom's macroglobulinemia. Clinical Lymphoma. 2005;5(4):270-272. [pmid: 15794863].
469 Dimopoulos MA, Zervas C, Zomas A, et al. Treatment of Waldenstrom's macroglobulinemia with rituximab. Journal of Clinical Oncology. 2002;20(9):2327-2333. [pmid: 11981004].
470 Dimopoulos MA, Zervas C, Zomas A, et al. Extended rituximab therapy for previously untreated patients with Waldenstrom's macroglobulinemia. Clinical Lymphoma. 2002;3(3):163-166. [pmid: 12521393].
471 Gertz MA, Rue M, Blood E, et al. Multicenter phase 2 trial of rituximab for Waldenstrom macroglobulinemia (WM): an Eastern Cooperative Oncology Group Study (E3A98). Leukemia & Lymphoma. 2004;45(10):2047-2055. [pmid: 15370249].
472 Ghobrial IM, Fonseca R, Greipp PR, et al. Initial immunoglobulin M 'flare' after rituximab therapy in patients diagnosed with Waldenstrom macroglobulinemia: an Eastern Cooperative Oncology Group Study. Cancer. 2004;101(11):2593-2598. [pmid: 15493038].
473 Hensel M, Villalobos M, Kornacker M, et al. Pentostatin/cyclophosphamide with or without rituximab: an effective regimen for patients with Waldenstrom's macroglobulinemia/lymphoplasmacytic lymphoma. Clinical Lymphoma & Myeloma. 2005;6(2):131-135. [pmid: 16231851].
474 Treon SP, Emmanouilides C, Kimby E, et al. Extended rituximab therapy in Waldenstrom's macroglobulinemia. Annals of Oncology. 2005;16(1):132-138. [pmid: 15598950].
475 Dimopoulos M, Anagnostopoulos A, Kyrtsonis M, et al. Primary treatment of Waldenstrom's Macroglobulinemia (WM) with Dexamethason, Rituximab, and Cyclophosphamide. Blood. 2006;108(11). Abstract #128.
476 Vargaftig J, Pegourie-Bandelier B, Mahe B, et al. Fludarabine plus cyclophosphamide and rituximab (RFC) in Waldenstrom's Macroglobulinemia (WM): Results in 21 patients (pts). Blood. 2006;108(11). Abstract #4727.
477 Abonour R, Zhang L, Rajkumar V, et al. Phase II pilot study of Rituximab + CHOP in patients with newly diagnosed Waldenstrom's Macroglobulinemia, an Eastren Cooperative Oncology Group Trial (Study E1A02). Blood. 2007;110(11). Abstract #3616.
478 Ghobrial I, Padmanabhan S, Badros A, et al. Phase II trial of combination of bortezomib and rituximab in relapsed and/or refractory Waldenstrom's Macroglobulinemia: Preliminary results. Blood. 2007;110(11). Abstract # 4494.
479 Laszlo D, Rabascio C, Andreola G, et al. Expression of the human concentrative nucleotide transporter (hCNT1) gene correlates with clinical response in patients affected by Waldenstrom's Macroglobulinemia (WM), undergoing a combination treatment with Cladribine (2-CdA) and Rituximab. Blood. 2007;110(11). Abstract #1357.
480 Tedeschi A, Miqueluiz S, Ricci F, et al. Fludarabine, Cyclophosphamide and Rituximab in Waldenstrom's Macroglobulinemia: An effective regimen requiring a new category of response criteria and a delayed assessment of results. Blood. 2007;110(11). Abstract #1290.
481 Soumerai J, Branagan A, Patterson C, et al. Long-term responses to thalidomide and rituximab in Waldenstrom's macroglobulinemia. Journal of Clinical Oncology. 2007;25(18S). Abstract #8017.
482 Amin CJ, Rabinowitz I. An unusual reoccurrence of Waldenstrom's macroglobulinemia as pleural effusions that had a discordant response with treatment. Clinical & Laboratory Haematology. 2005;27(3):200-202. [pmid: 15938727].
483 Bertazzoni P, Andreola G, Laszlo D, et al. Severe neuropathy in a patient with Waldenstrom disease: from a challenging diagnosis to clinical improvement by innovative therapy. Leukemia & Lymphoma. 2006;47(9):1970-1972. [pmid: 17065016].
484 Buda-Okreglak EM, Drabick JJ, Delaney NR. Proinflammatory syndrome mimicking acute rheumatoid arthritis in a patient with Waldenstrom's macroglobulinemia treated with rituximab. Annals of Hematology. 2004;83(2):117-119. [pmid: 14513285].
485 Ghobrial IM, Uslan DZ, Call TG, et al. Initial increase in the cryoglobulin level after rituximab therapy for type II cryoglobulinemia secondary to Waldenstrom macroglobulinemia does not indicate failure of response. American Journal of Hematology. 2004;77(4):329-330. [pmid: 15551276].
486 Gironi M, Saresella M, Ceresa L, et al. Clinical and immunological worsening in a patient affected with Waldenstrom macroglobulinemia and anti-mag neuropathy after treatment with rituximab. Haematologica. 2006;91(6 Suppl):ECR17. [pmid: 16785123].
487 Iyer A, Mathur R, Deepak BV, et al. Fatal adenoviral hepatitis after rituximab therapy. Archives of Pathology & Laboratory Medicine. 2006;130(10):1557-1560. [pmid: 17090202].
488 Khaled Y, Hanbali A. Hepatitis B virus reactivation in a case of Waldenstrom's macroglobulinemia treated with chemotherapy and rituximab despite adefovir prophylaxis. American Journal of Hematology. 2007;82(7):688. [pmid: 17366549].
489 Liberato B, Riethmuller A, Comenzo RL, et al. Myelopathy from Waldenstrom's macroglobulinemia: improvement after Rituximab therapy. Journal of Neuro-Oncology. 2003;63(2):207-211. [pmid: 12825826].
490 Mohammad RM, Aboukameel A, Nabha S, et al. Rituximab, Cyclophosphamide, Dexamethasone (RCD) regimen induces cure in WSU-WM xenograft model and a partial remission in previously treated Waldenstrom's macroglobulinemia patient. Journal of Drug Targeting. 2002;10(5):405-410. [pmid: 12442811].
491 Mori A, Tamaru J-I, Kondo H. Effects of rituximab on a patient with Waldenstrom's macroglobulinaemia with deletion 13q14. European Journal of Haematology. 2002;69(5–6):321-323. [pmid: 12460239].
492 Mori A, Tamaru J-I, Sumi H, et al. Beneficial effects of rituximab on primary cold agglutinin disease refractory to conventional therapy. European Journal of Haematology. 2002;68(4):243-246. [pmid: 12071942].
493 Noronha V, Fynan TM, Duffy T. Flare in neuropathy following rituximab therapy for Waldenstrom's macroglobulinemia. Journal of Clinical Oncology. 2006;24(1):e3. [pmid: 16382111].
494 Pearlman AN, Fechner FP, Constantinides M. Development of nasal skin necrosis associated with rituximab treatment for Waldenstrom's macroglobulinemia and subsequent spontaneous resolution. Ear, Nose, & Throat Journal. 2006;85(7):431-433.
495 Treon SP, Agus TB, Link B, et al. CD20-directed antibody-mediated immunotherapy induces responses and facilitates hematologic recovery in patients with Waldenstrom's macroglobulinemia. Journal of Immunotherapy. 2001;24(3):272-279.
496 Treon SP, Branagan AR, Hunter Z, et al. Paradoxical increases in serum IgM and viscosity levels following rituximab in Waldenstrom's macroglobulinemia. Annals of Oncology. 2004;15(10):1481-1483. [pmid: 15367407].
497 Treon SP, Hunter Z, Barnagan AR. CHOP plus rituximab therapy in Waldenstrom's macroglobulinemia. Clinical Lymphoma. 2005;5(4):273-277. [pmid: 15794864].
498 Treon SP, Shima Y, Preffer FI, et al. Treatment of plasma cell dyscrasias by antibody-mediated immunotherapy. Seminars in Oncology. 1999;26(5 Suppl 14):97-106. [pmid: 10561024].
499 Weber DM, Dimopoulos MA, Delasalle K, et al. 2-Chlorodeoxyadenosine alone and in combination for previously untreated Waldenstrom's macroglobulinemia. Seminars in Oncology. 2003;30(2):243-247. [pmid: 12720145].
500 Weide R, Heymanns J, Koppler H. The polyneuropathy associated with Waldenstrom's macroglobulinaemia can be treated effectively with chemotherapy and the anti-CD20 monoclonal antibody rituximab. British Journal of Haematology. 2000;109(4):838-841. [pmid: 10929038].
501 Zinzani PL, Tani M, Alinari L, et al. Waldenstrom's macroglobulinemia: is there a place and time for a cease-fire?. Leukemia Research. 2003;27(5):465-466. [pmid: 12620298].