# Results

## Search Results

The electronic literature search yielded 47 unique records, of which 33 were excluded at initial title and abstract review and 14 were retrieved for full-text examination. Based on the study selection criteria, 6 articles met inclusion criteria. However, the electronic search did not include publications available from the FDA. Subsequent to the search, one RCT was published.11 Search of a bibliography of a review article revealed one additional article that met entry criteria.13 We decided to include an unpublished RCT in which results are published in a conference abstract.23 One publication reported pooled findings of two studies.24 One published study reported results for two indications for use of sipuleucel-T.12 Review of conference abstracts revealed pooled analyses of previously identified clinical trials.25–28 Due to lack of sufficient information and data presentation in these abstracts, we did not include them in this review.

Therefore, it is most clear to report search results in terms of the number of independent patient data sets found, rather than the number of publications. For Key Question 1, there are three independent data sets reported in three peer-reviewed publications and several documents available from the FDA website.11, 17, 24, 29–33 For Key Question 2, there are seven sets of findings from five peer-reviewed publications and a conference abstract.12–14, 23, 34–36 For Key Question 3, we relied on one set of pooled findings from an FDA clinical review.17

## Synthesis of Evidence for Key Questions

### Key Question 1 What is the evidence regarding the clinical outcomes of sipuleucel-T for its FDA-approved indication; asymptomatic or minimally symptomatic metastatic androgen independent prostate cancer?

Evidence regarding this question consists of three RCTs, published in various documents and to greater or lesser depth in numerous forms.10, 11, 17, 24, 29–33 To identify the studies consistently, we designate the studies as “IMPACT,” “D9901,” and “D9902A,” throughout this technology assessment, regardless of the source of the information.

Abstraction of key results for this technology assessment was complicated by the multiple sources. These sources included peer-reviewed journal publications, FDA-authored clinical reviews, FDA-authored statistical reviews, and company-authored briefing documents prepared for FDA committee meetings.

At least two issues arise from this quantity of published materials regarding the performance of this technology assessment. One issue is a problem with potentially discordant results seeming to arise out of what appears to be the same analysis. Such issues could arise from error, slight differences in the data used, such as different cutoff date, or minor selection criteria. We noticed several instances where calculations varied beyond the tenth place in a decimal calculation. We used the peer-reviewed publication value whenever there was discordance.

Another issue is the presentation of alternative or “sensitivity” analyses, which are variations on a particular analysis usually meant to support the validity of the primary analysis. These are sometimes problematic, because they are usually performed post-hoc, often incompletely described and presented, and may be inappropriate. There are many such analyses in the published materials we reviewed for this assessment. Presentation of all these analyses may give the impression that there is more evidence than there really is. Analyses based on the same data set are obviously highly correlated; the unmeasured biases of that study exist across all analyses. In these materials, it is evident that some analyses performed by FDA statisticians on the clinical trial data were meant to critique the validity of the sensitivity analyses performed by the sponsor. Points of contention raised by competing statistical analyses raise issues that may not be solvable, but point to an underlying uncertainty in the conclusions of a particular analysis.

Rather than attempt to abstract all these analyses, we decided to try to characterize and summarize these analyses in brief form in Appendix A. The tables accompanying the text within this document will focus on what we consider to be the principal results of the studies.

Finally, the studies were not fully independent investigations, although they will be presented as such. Decisions regarding outcome measures, selection criteria, and analysis were made based on the findings of the earlier studies. For example, because study D9901 did not attain statistical significance for its original end point of progression-free survival, enrollment for study D9902A was terminated; thus, its sample size is smaller than originally planned. Because of results obtained from analyses of D9901 and D9902A, the principal outcome of IMPACT was changed to overall survival, and selection criteria for the study were altered.

The D9901 and D9902A study results were pooled for analysis in a peer-reviewed publication and in publications prepared for the FDA.10, 24 Several conference abstracts consisted of analyses of pooled data.25–28 We will not routinely present these pooled analyses because the pooled analyses do not really represent additional independent evidence. Certain analyses appear to be only available from these pooled analyses, and we will present as necessary.

#### Study Design of IMPACT, D9901, and D9902A

All three studies had very similar structure, except for minor variations in entry criteria and nonsurvival outcome measures. Patients were randomized 2:1 to either sipuleucel-T or placebo. Patients had leukapheresis and infusion at weeks 0, 2, and 4, and then were followed for study end points. Placebo patients underwent identical leukapheresis at the same intervals, but received infusions of about one-third of their untreated cells back as placebo. The remaining two-thirds of their cells were cryopreserved. After disease progression occurred in the placebo group, they were offered the opportunity to receive a salvage product consisting of their own cells, which were then thawed and prepared in a similar method as sipuleucel-T. In addition to being prepared from cryopreserved cells, another difference between frozen salvage product and sipuleucel-T is that the frozen cells have never been exposed to circulating sipuleucel-T in the patient’s body. In the treatment groups of the clinical trial, the cells extracted at the second and third leukapheresis sessions are drawn from subjects who have had prior exposure to sipuleucel-T from the first dose. Upon disease progression in both groups, patients could be treated at the discretion of their own treating physicians.

The design of the study raises some issues regarding internal validity. First, the leukapheresis and placebo infusion is not a truly inert placebo. Complications could occur, and this should be considered in understanding the adverse effects of sipuleucel-T. Second, effects either positive or negative of frozen salvage product could affect the validity of the study. In many randomized studies therapies, patients are often offered to “cross over” to active treatment. If the cross-over treatment has a treatment effect in the same direction as the original treatment, then in most cases a conservative bias would result, so that the usual intention-to-treat analysis of the trial would result in a conservative estimate of treatment effect. Third, treatment administered after disease progression could potentially confound the results if the provision of effective treatments varies between the active and placebo-treated groups.

#### Patients

The principal entry criterion for the studies was metastatic castrate-resistant prostate cancer. Studies D9901 and D9902A enrolled asymptomatic patients, IMPACT enrolled asymptomatic and minimally symptomatic patients (Appendix Table A1). “Minimally symptomatic” was defined as not requiring opioid analgesics within 21 days of registration, and an average weekly pain score of less than 4 on a 10-point visual analog scale on the registration pain log. Other aspects of the selection criteria are specifically stated in various protocol documents, but can be characterized as selection of patients in reasonably good health (e.g., good ECOG performance scores, expected survival of at least 6 months), without signs of prognostically poor disease (i.e., without visceral metastases, long bone fractures, or spinal cord progression), reasonably distant in time from prior chemotherapy (various criteria for recency of prior therapy), and normal immunologic function (various laboratory and serology values).30, 37

The entry criteria Gleason score for IMPACT was changed during the trial from 7 or less to any Gleason score. Thus, compared to D9901 and D9902A, IMPACT enrolled a higher proportion of subjects with Gleason scores of 7 or less.

#### Outcomes

All trials reported overall survival. However, studies D9901 and D9902A were designed for an end point of progression-free survival, and the primary end point of IMPACT was changed from progression-free survival to overall survival. The design of the studies reflects the emphasis on the original progression end point, with rigorous efforts to blind patients and investigators and objective criteria to determine progression. After progression, there were fewer guidelines regarding patient management.

The progression end point varied slightly between each of the studies, but largely involved evaluation of lesions observed on serial bone scans and computed tomography. IMPACT considered only imaging results in the assessment of disease progression; D9901 and D9902A considered imaging and certain clinical events such as lesion-associated onset of pain as progression events.

Quality of life was not specifically assessed in any of the studies. The protocols for studies D9901 and D9902A include secondary end points of time to onset of disease-related pain and time to clinical progression.

Adverse events were collected using standard methods up to 16 weeks (in D9901 and D9902A) or until disease progression (in IMPACT). After this interval, adverse events with the exception of cerebrovascular events were only collected if it was determined by the investigators to be possibly related to sipuleucel-T treatment. Causes of death were apparently collected and analyzed, but there is no description in any protocol documents regarding an algorithm for determining cause of death or an adjudication process. Descriptions of some case reports in documents reveal that death certificate data was used as the source of information for cause of death for at least some subjects.

#### Results of IMPACT, D9901, D9902A

IMPACT enrolled 512 patients, D9901 enrolled 127 patients, and D9902A enrolled 98 patients. In terms of the quality rating of the studies, in many attributes the studies are good quality. In terms of the original disease progression end point, the studies would overall be good quality. However, because of potential confounding effects occurring after disease progression, they received a fair rating for the study end point of survival (Appendix Table A2).

Baseline characteristics appear to be reasonably balanced between sipuleucel-T and placebo groups in all the studies. Although IMPACT enrolled patients with minimal symptoms and the other trials only enrolled asymptomatic patients, the mean ECOG performance scores of patients enrolled in IMPACT equal or surpass those of patients in the other trials. The original strict Gleason score criteria of the IMPACT trial resulted in a higher proportion of patients with more favorable Gleason scores. Also notable among the baseline characteristics is that 18 percent of subjects in IMPACT had undergone prior chemotherapy, whereas lower proportions of subjects in D9901 and D9902A had undergone chemotherapy. This might be due to the slightly different exclusion criteria regarding history of prior chemotherapy. There do not appear to be outstanding differences in other patient characteristics and disease status between IMPACT, D9901, and D9902A.

Overall survival outcomes of all three trials are shown in Table 1. All studies followed patient survival end points until over 67 percent of patients had died. In all three studies, the median survival of the sipuleucel-T groups was greater than the survival of the placebo groups. The difference in median survival between groups was 4.1 months in IMPACT, 4.5 months in D9901, and 3.3 months in D9902A. However, in D9902A, survival times were shorter in both sipuleucel-T and placebo groups, such that the median survival time in the sipuleucel-T group was shorter than the placebo groups from the other 2 trials. There does not appear to be any difference in patient characteristics in this trial to explain this difference in survival times. However, given the relatively small sample size of the study, the result could be due to chance. The hazard ratio for death calculated from a Cox proportional hazard model shows a reduction in mortality for sipuleucel-T treated groups of 0.77, 0.59, and 0.79, from the IMPACT, D9901, and D9902A studies, respectively. These differences were statistically significant for the IMPACT and D9901, but not significant for the D9902A. The same results expressed as survival probability at 36 months after randomization are shown in Table 2. Issues regarding variations and alternative formulations of these survival analyses are discussed in Appendix Table A3. We did not feel these alternative analyses particularly strengthened or weakened these principal overall survival results.

Table 1 Principal Overall Survival Outcomes of RCTs of Sipuleucel-T for the FDA-Approved Indication

Study (ref) | Sample size | Number of deaths by study close- out | Median survival sipuleucel-T group (months) | Median survival placebo group (months) | Hazard ratio (<1 indicates survival in favor of sipuleucel-T) | Confidence interval and p value
IMPACT (11) | Sipuleucel-T (n=341) | 210 | 25.8 | 21.7 | 0.78 prespecified adjusted | 0.61–0.98, p=0.03
IMPACT (11) | Placebo (n=171) | 121 | 25.8 | 21.7 | 0.78 prespecified adjusted | 0.61–0.98, p=0.03
D9901 (25) | Sipuleucel-T (n=82) | 54^**^ | 25.9 | 21.4 | 0.59 unadjusted^*^ | 0.39–0.88, p=0.01
D9901 (25) | Placebo (n=45) | 40 | 25.9 | 21.4 | 0.59 unadjusted^*^ | 0.39–0.88, p=0.01
D9902A (10) | Sipuleucel-T (n=65) | 44^**^ | 19.0 | 15.7 | 0.79 unadjusted^*^ | 0.48–1.28, p=0.33
D9902A (10) | Placebo (n=33) | 26 | 19.0 | 15.7 | 0.79 unadjusted^*^ | 0.48–1.28, p=0.33

* Hazard ratio and confidence interval presented is 1/hazard ratio from published source, to be consistent with hazard ratio from IMPACT

** deaths before 36 months

Table 2 Estimated Probability of Survival at 36 Months in RCTs of Sipuleucel-T for the FDA-Approved Indication

Study (ref) | Sipuleucel-T group estimated survival probability (%) | Placebo group estimated survival probability (%)
IMPACT (11) | 31.7 | 23.0
D9901 (25) | 34.1 | 10.7
D9902A (10) | 31.6 | 21.2

The principal disease progression end points for each of the studies are shown in Table 3. The hazard ratio for progression was 0.95 in IMPACT, 0.69 in D9901, and 0.92 in D9902A. None of these hazard ratios met a 0.05 level of statistical significance. The difference in median time to progression was 0.2 weeks in IMPACT, 1.7 weeks in D9901, and 1.0 weeks in D9902A.

A pooled analysis of D9901 and D9902A was performed for a secondary end point of time to pain progression. However, this analysis is limited by censoring; patients only completed a pain and analgesic log 4 weeks beyond the time of disease progression. This resulted in almost two-thirds of patients being censored because there were no pain events within 4 weeks after disease progression. Nonetheless, 79 pain events consistent with cancer progression occurred in 225 patients. Median time to pain progression was 33.9 weeks for sipuleucel-T subjects and 32.7 weeks for placebo subjects, which was not statistically significant (p=0.719). An analysis of time to clinical progression of subjects in D9901, basically a slight variation of the principal disease progression analysis, showed no difference in median time to clinical progression.

#### Consideration of Post-Progression Treatments

After progression, a high proportion of subjects in the placebo groups received frozen salvage product; 63.7 percent in IMPACT, 75.6 percent in D9901 and 66.7 percent in D9902A (Table 4). In IMPACT, the median survival for subjects receiving frozen salvage product was 23.8 months and 11.6 months for those who did not. This comparison should not be used to infer a potentially beneficial effect of frozen salvage product, because it is not randomized and is subject to survivor bias. Assignment to the frozen salvage product group is conditional on survival up to the point of receipt of that treatment, producing a survivor bias Any simple comparison of survival of two groups in which group membership is defined by events occurring after baseline will be biased. Such a survival bias cannot be removed by adjustment for patient characteristics.

Some patients in both groups received subsequent chemotherapy treatments after progression, including docetaxel chemotherapy, which has been demonstrated to have a survival benefit in RCTs. The proportion of patients receiving docetaxel chemotherapy in each trial is shown in Table 4. In IMPACT, a greater proportion of sipuleucel-T-treated patients received docetaxel chemotherapy (57.2 percent versus 50.3 percent), and they also received it earlier (median 7.2 months versus 9.6 months). In D9902A, slightly more sipuleucel-T treated-patients received docetaxel (38.6 percent versus 34.4 percent), but in D9901, more placebo-treated patients received docetaxel (47.6 percent versus 35.9 percent). The difference in median time to receipt of docetaxel in IMPACT might be partially explained by the use of frozen salvage product in the placebo group, which requires one month to administer.

Analyses were presented to attempt to adjust for these potential confounding effects of subsequent docetaxel treatment. Results of these analyses are shown in Table 5. In one type of analysis, patients are removed (“censored”) from the study upon docetaxel initiation. Assuming that the patients censored are similar to the patients not censored, such an analysis intends to estimate the survival of patients who did not receive docetaxel. This analysis of the IMPACT data showed a treatment effect hazard ratio of 0.649, which was statistically significant (p=0.009). Another analysis of IMPACT data using a time-dependent variable indicating the use and time of docetaxel use showed a hazard ratio of 0.777 which was also statistically significant (p=0.034). An analysis with time-dependent variables assumes that patients who receive docetaxel are similar to patients who do not receive docetaxel, and that their estimated survival is altered by some fixed magnitude upon receiving docetaxel treatment. Analyses of D9901 and D9902A, which are likely to be time-dependent analyses, show similar magnitudes of treatment hazard ratio of sipuleucel-T to the other analyses, but do not meet the standard level of statistical significance.

Table 3 Principal Disease Progression Outcomes and Other Secondary Outcomes of RCTs of Sipuleucel-T for the FDA-Approved Indication

Study (ref) | Median time of progression sipuleucel-T group (weeks) | Median time of progression placebo group (weeks) | Hazard ratio | Confidence interval and p value
IMPACT (11) | 14.6 | 14.4 | 0.95 unadjusted | 0.77–1.17, p=0.63
D9901 (25) | 11.7 | 10.0 | 0.69 unadjusted^*^ | 0.47–1.01, p=0.052
D9902A (26) | 10.9 | 9.9 | 0.92 unadjusted^*^ | 0.59–1.45, p=0.72
Pooled D9901 and D9902A (26) Time to pain progression (secondary disease progression analyses) | 33.9 | 32.7 | Not reported | 0.719
D9901 (26) Time to clinical progression (secondary disease progression analyses) | 10.7 | 9.1 | Not reported | 0.061

* Hazard ratio and confidence presented is 1/hazard ratio from published source, to be consistent with hazard ratio from IMPACT

Table 4 Percentage Receipt and Median Time to Receipt of Post-progression Treatments in RCTs of Sipuleucel-T for the FDA-Approved Indication

Study | % placebo group receiving Frozen Salvage Product | Median time to receipt of Frozen Salvage Product (months) | Treatment group | % each group receiving docetaxel chemotherapy | Median time to receipt of docetaxel chemotherapy (months | % of each group receiving any other treatment besides Frozen Salvage Product | Median time to receipt of any other treatment besides Frozen Salvage Product (months)
IMPACT (17) | 63.7 | 5.7 | Sipuleucel-T | 57.2 | 7.2^*^ | 81.8 | NA
IMPACT (17) | 63.7 | 5.7 | Placebo | 50.3 | 9.6^*^ | 73.1 | NA
D9901 (24,25,28) | 75.6 | 4.6^**^ | Sipuleucel-T | 35.9 | NA | 54.4 | NA
D9901 (24,25,28) | 75.6 | 4.6^**^ | Placebo | 47.6 | NA | 62.8 | NA
D9902A (24,25,28) | 66.7 | 4.6^**^ | Sipuleucel-T | 38.6^***^ | NA | 66.7^***^ | NA
D9902A (24,25,28) | 66.7 | 4.6^**^ | Placebo | 34.4^***^ | NA | 54.5^***^ | NA

* Numbers differ from published article. Published article cites Kaplan-Meier estimate of median time to chemotherapy, which takes into account censoring due to death and/or end of follow-up.

** Number not available directly, number provided is from pooled analysis of D9901 and D9902

*** Number not available directly, estimated by subtracting numbers from D9901 from pooled (D9901 + D9902A)

Table 5 Alternative Analyses Taking into Account Incidence and Time of Docetaxel Treatment after Disease Progression

Sensitivity analysis | Study (ref) | Treatment effect hazard ratio (95% CI) | p value
Censor patients at time of docetaxel initiation | IMPACT (11) | 0.649 (0.469, 0.898) | 0.009
Time-dependent covariate for docetaxel use | IMPACT (11) | 0.777 (0.615, 0.981) | 0.034
“adjustment for time to docetaxel chemotherapy”^*^ | D9901 (10) | 0.649 (0.420, 1.000) | 0.052
“adjustment for time to docetaxel chemotherapy”^*^ | D9902A (10) | 0.667 (0.398, 1.111) | 0.121

* Methodology not specifically stated, most likely time-dependent covariate for docetaxel use

Although these analyses show a statistically significant treatment hazard ratio of sipuleucel-T similar in magnitude to the primary analyses, it is not certain that they can fully account for the potential confounding effects of docetaxel treatment. They do not account for potential differences between treatment regimens in terms of dose or length of treatment. The analyses require assumptions of the events which are not observable in the trial. The usual assumption of an analysis censoring subjects at the time of docetaxel use is that the censoring time provides no further information about the subjects’ likelihood of future survival. Survival curves will be biased unless those who were censored for docetaxel use have similar expected survival to those who were not censored for docetaxel use. This assumption is implausible, since docetaxel is a treatment for disease progression. However, the effect of this bias on the estimate of the relative effect of sipuleucel-T on survival would depend on the degree of this bias in each treatment arm. It could be possible that each treatment arm is similarly affected by this bias, producing an unbiased estimate of treatment effect. Time-dependent analyses also assume that the change of exposure and its timing are not related to the probability of future survival. The particular analytic issue in these studies is called” time-dependent confounding,” and analytic techniques known as marginal structural models have been proposed as a method to overcome the potential biases that can occur under these circumstances.38 (Personal communication, Bryan Shepherd, Ph.D., October 2010)

In sum, in three trials of similar design, all three studies showed improved median and 36-month survival of sipuleucel-T-treated subjects compared to placebo-treated subjects. In two of the studies, the difference met traditional levels of statistical significance. The third smaller study did not meet statistical significance. The third study has showed overall shorter survival times, but chance or other unmeasured difference in study participants could explain the finding. There was no difference in disease progression end points. Analyses undertaken to account for potential confounding effects of subsequent treatments did not change the magnitude or statistical significance of the findings, but such methods may be limited in the ability to fully account for such effects. A synthesis of the evidence for the FDA-labeled indication using the modified AHRQ/GRADE framework is shown in Appendix Table A4. The body of evidence was graded as moderate. The principal reason for the moderate grade is the risk of bias due to the unequal provision of subsequent treatments. The trial design resulted in a systematic bias against the control group due to a delay induced by treatment with frozen salvage product. The statistical methods used to account for subsequent treatments are limited in that time-dependent confounding effects cannot be accounted for.

### Key Question 1a For the FDA-labeled indication, what is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

Examination of treatment effects in separate subgroups may provide insight regarding possible treatment modifiers. If such effects are significant and biologically plausible, they may affect recommendations for treatment in specific types of patients. However, examination of subgroup effects is subject to statistical problems. Because of small sample sizes of particular subgroups, the statistical power to obtain statistically significant interactions is low. Because of the potentially large number of possible subgroup analyses, any particular finding may be due to chance. Because two of the three sipuleucel-T RCTs were fairly small in size, these problems are compounded. Thus it is unlikely that examination of subgroup effects in these trials would generate any definitive findings unless the underlying treatment interactions were extremely strong. Any suggestion of a subgroup effect in these analyses would require further research and confirmation.

Treatment effects by baseline characteristics of patients are only presented in graphical form in any of the documents reviewed for this technology assessment (Appendix B). In Higano et al., subgroup effects by baseline patient characteristics were shown for a combined analysis of studies D9901 and D9902A (Appendix Figure B1).24 The same baseline characteristics are examined for study D9901 alone in the Dendreon briefing document.10 Many of the of the subgroup pairings show that the hazard ratio estimate is different depending on the subgroup comparison. For example, the most extreme difference depicted in the pooled analysis in Appendix Figure B1 is the analysis categorizing bone metastases. The group with 10 or fewer metastases shows a hazard ratio of greater than 2, indicating a strong effect of sipuleucel-T, whereas the group with more than 10 metastases shows a much weaker effect, probably close to 1.3 by visual estimation. If these point estimates were correct in terms of an actual interaction, it would mean that sipuleucel-T is very beneficial to patients with 10 or fewer metastases, and not very beneficial to patients with more than 10 metastases. However, the broad confidence intervals encompassing each subgroup hazard ratio preclude any conclusions or signals of subgroup treatment effects. It cannot be determined whether any large difference between the two hazard ratios between any pair of subgroups is due to random variation (chance) or a real interaction.

A more extensive set of treatment effects by baseline characteristics was examined for the IMPACT trial (Appendix Figure B2). The broad confidence intervals surrounding most subgroup hazard ratios preclude raising significant concerns or suspicions regarding subgroup effects. The only exception to this is the analysis dividing the subjects of the IMPACT trial in age groups divided at 65 years of age. In the subgroup of subjects who were younger than 65 years, the hazard ratio was 1.411 (95 percent CI: 0.869–2.290), in the direction of harm of sipuleucel-T. The value of the hazard ratio for those 65 or older was not reported in any of the documents, but graphically its value was greater (closer to zero) than the overall hazard ratio for sipuleucel-T treatment effect, is it would have to be to counterbalance the 1.411 hazard ratio for the younger than 65 group. The confidence intervals of the two hazard ratios do not overlap, indicating a highly statistically significant interaction if using statistical tests uncorrected for multiple statistical testing.

The FDA statistical review did a further pooled analysis of this possible age interaction using the pooled data from studies D9901, D9902A, and IMPACT. The results are shown below in Table 6.

Table 6 Subgroup analysis by age in pooled trials D9901, D9902A, and IMPACT

Group | Sipuleucel-T median survival (95% CI) | Placebo group median survival (95% CI) | Hazard ratio (95% CI)
Younger than 65 years | 29.0 (22.8, 34.2) | 28.2 (23.4, 32.5) | 0.919 (0.618, 1.366)
65 years or older | 23.4 (22.0, 27.1) | 17.3 (13.5, 21.4) | 0.661 (0.538, 0.813)

The pooled analysis shows a less extreme difference in the treatment effect in the two age groups, as the pooled hazard ratio for the younger than 65 age group is now in the direction of benefit of sipuleucel-T. However, estimate of benefit is less than the estimate for the subjects over age 65. It is inconclusive whether there is a treatment interaction with age at a cutoff of age 65.

In another analysis of pooled data, the FDA examined racial subgroups, and found consistent treatment benefit in Caucasian, African American, and other racial categories. However, the “other” racial category hazard ratio was not significant, mostly likely due to very small number of subjects in this category (a total sample size of 28).

In conclusion, limitations of sample size and multiple subgroup comparisons make it difficult to make inferences regarding the potential interaction of sipuleucel-T and baseline patient characteristics. A significant interaction with age group at an cutoff age of 65 was observed in the IMPACT results showing a qualitative interaction with hazard ratios indicating harm for those younger than 65 years and benefit for those 65 years or older. These subgroup differences became less extreme when all the clinical trial data was pooled, making the finding inconclusive.

#### Association of Cell Product Parameters, Patient Immune Response, and Patient Outcome

Although the dose of sipuleucel-T is not controlled or manipulated except to determine a minimum cell number in a dose, several measures of the product have been analyzed in relation to patient outcomes. It is uncertain what value these analyses have in the determination of the overall effectiveness of sipuleucel-T or if there is any clinical value to the associations found.

The analyses performed have all assessed product parameters and patient outcomes using only the sipuleucel-T-treated groups. The parameters that have been measured include the CD54 upregulation ratio, the total nucleated cell count, and the CD54 cell count, all analyzed as a cumulative total of these measures across the three doses given. Differentiating between a treatment effect versus a characteristic associated with inherent survival would require knowledge and analysis of these product parameters in the untreated control groups. Several of the types of measurements are not available or are probably not possible to do in untreated control groups. For example, in order to measure CD54 upregulation in placebo patients in the same way as in sipuleucel-T-treated subjects, the placebo patients’ cells would need to be assayed for CD54 before and after culture in the presence of PA2024. However, as placebo patients, they would not receive the treated cells. It would be impossible to measure CD54 upregulation after the initial dose of drug, because CD54 upregulation tends to increase after the first exposure to sipuleucel-T. It is impossible to know what a placebo patient’s CD54 upregulation would have been in subsequent doses of sipuleucel-T without treating them with an initial dose.

Table 7 shows a summary of the analyses of product parameters and patient survival reported from the three trials. In a pooled analysis of studies D9901 and D9902A, CD54 upregulation was correlated with survival and both unadjusted and analyses adjusted for baseline characteristics. Total nucleated cell count and CD54 count were not correlated with survival in final adjusted analyses. In the IMPACT study, the direction of the associations was similar to the prior pooled analysis, but the association between CD54 upregulation ratio and survival was not statistically significant, but the association between total nucleated cell count and survival was statistically significant. The results between the two studies show a consistent positive direction of associations, but apparently the strength of the association for a particular parameter varies between the studies. Confounding of the associations with unmeasured patient characteristics cannot be ruled out.

The table also shows some analyses reported from the IMPACT trial from a subset of subjects from that trial who had immune response assays performed. Two-hundred thirty-seven subjects had assay results available for antibody and T-cell proliferative responses to PA2024, PAP, and GM-CSF. These assays were done periodically up through week 26 of the study. Subjects with higher antibody responses to PA2024 and subjects with higher antibody responses to PAP had longer survival, but only the p value is reported. There were no associations between T-cell proliferation to PA2024 or PAP and survival. None of these analyses appear to have been adjusted for potential confounding variables.

In sum, some analyses of product parameters and patient immune responses show an association between the characteristic and survival, but the clinical significance of these associations are unknown. Because the biologic mechanism of the therapeutic effect of sipuleucel-T is not fully understood, these analyses do not inform the question of the overall efficacy of sipuleucel-T. The quantity of data and the analyses performed so far are not sufficient to determine whether such product parameters or measures of patient immune response are clinically useful.

Table 7 Association of Sipuleucel-T Product Parameters and Patient Immune Response Measures and Patient Survival

Study (ref) | Product parameter/Patient immune response parameter | Measure of association | Value of association | p value
Pooled D9901 and D9902A (10) Product parameters | Cumulative CD54 upregulation ratio | Continuous, in Cox survival analysis | NR, positive correlation | 0.009 unadjusted
Pooled D9901 and D9902A (10) Product parameters | Cumulative CD54 upregulation ratio | Continuous, in Cox survival analysis | NR, positive correlation | 0.022 adjusted
Pooled D9901 and D9902A (10) Product parameters | Total nucleated cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.018 unadjusted
Pooled D9901 and D9902A (10) Product parameters | Total nucleated cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.138 adjusted
Pooled D9901 and D9902A (10) Product parameters | CD54 cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.354 unadjusted
Pooled D9901 and D9902A (10) Product parameters | CD54 cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.694 adjusted
IMPACT (10) Product parameters | Cumulative CD54 upregulation ratio | Continuous, in Cox survival analysis | NR, positive correlation | 0.123
IMPACT (10) Product parameters | Total nucleated cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.008
IMPACT (10) Product parameters | CD54 cell count | Continuous, in Cox survival analysis | NR, positive correlation | 0.016
IMPACT (11) Immune response parameters | Antibody titer against PA2024 | >400 vs. ≤400, log-rank test | NR, >400 better survival | <0.001
IMPACT (11) Immune response parameters | Antibody titer against PAP | >400 vs. ≤400, log-rank test | NR, >400 better survival | 0.08
IMPACT (11) Immune response parameters | T-cell proliferation assay PA2024 | Unspecified, likely stimulation index >5 vs. ≤5, log-rank test | No association | NR
IMPACT (11) Immune response parameters | T-cell proliferation assay PAP | Unspecified, likely stimulation index >5 vs. ≤5, log rank test | No association | NR

#### Consideration of Treatment Effect of Sipuleucel-T and Post-progression Chemotherapy

In a prior section of this technology assessment, it was considered whether post-progression chemotherapy was a potential confounder in determining the treatment effect of sipuleucel-T. It may also be of interest to determine if there is an interaction of sipuleucel-T and post-treatment chemotherapy. That is, is there a differential effectiveness of sipuleucel-T depending on whether post-treatment chemotherapy is given or not?

Unfortunately, given the data and analysis available, this is difficult to determine. Examination of the survival curves of each initial and subsequent treatment group (sipuleucel-T/placebo, no docetaxel/docetaxel) may be biased by potential confounding and survival biases. The groups receiving post-progression docetaxel survive longer than the other groups because receiving such treatment was conditional on being alive to receive such treatment. If sipuleucel-T is effective, then it is effective in a context in which a substantial proportion of patients receive subsequent chemotherapy. Determination of the independent and/or interactive effects of sipuleucel-T and subsequent therapies would require further study using study designs where patients are randomized to subsequent treatments or data collection and analyses are performed which can account for time-dependent confounding variables.

### Key Question 2 What is the level of evidence and summary of evidence for off-label indications for sipuleucel-T?

Many of the studies of sipuleucel-T in which patients not meeting the FDA-labeled indications were enrolled were early Phase I and II studies which did not have control groups. They were largely intended to assess potential biologic activity, immune response, and safety, and thus were not intended to provide definitive evidence for efficacy. They may have not been designed or conceived with strict treatment indications in mind. The shortcomings of those studies in determining efficacy should be viewed in this light. In addition, the dose and scheduling of treatment differed from the three RCTs previously reviewed for the on-label indication. The manufacturing process and quality control criteria may have differed from the currently available treatment.

We found seven sets of findings reported in five peer-reviewed publications and one conference abstract. One publication reports findings for two groups of patients. The description of the patients included in the studies, and therefore, the implied indications are:

- Metastatic castrate-resistant prostate cancer, but unspecified symptoms
- Nonmetastatic castrate-resistant prostate cancer
- Nonmetastatic hormone-sensitive prostate cancer

Brief summaries of the patient characteristics, treatment protocol, clinical and other outcomes are shown in Appendix Table A5. All the studies with the exception of the conference abstract are single-arm case series studies. The conference abstract is an RCT with relatively little description of the subjects and results available. Thus we did not do a formal quality rating of the studies, which is generally applicable to comparative treatment studies.

#### Metastatic Castrate-Resistant Prostate Cancer, but Unspecified Symptoms

Three case series comprising a total of 46 patients are reported.12–14 The symptom status of the patients is not reported. However, the ECOG performance scores of the patients fall into the same range as those in the three previously reported clinical trials, so it is likely that these patient characteristics largely overlap with those in the RCTs for the labeled indication.

The clinical outcome reported in these case series was median time to progression. This varied between the studies from 12 to 19.3 weeks (Table 8). The protocols for assessing progression varied between the studies and were not always clearly explained in the studies. Given the lack of a control group, the studies do not provide information regarding the efficacy of sipuleucel-T in this patient group.

Other nonclinical outcomes included measurement of changes in PSA and assessments of T-cell proliferative responses to PA2024 and prostate antigens. T-cell proliferation increased from before treatment to after treatment. A few patients had PSA declines. However, the utility of PSA change as a marker of treatment response became questionable, as it was noted in both the study of Burch et al. (2000)13 and Burch et al. (2004)14 that a 50 percent decline in PSA in one patient in each study was accompanied by observable disease progression. One patient in Burch et al (2000)13 had a fall in PSA to an undetectable level followed by regression and disappearance of metastatic disease.

Table 8 Results of Case Series of Sipuleucel-T in Metastatic Castrate-Resistant Prostate Cancer, Unspecified as to Symptoms

Study (ref) | Sample size | Median time to progression | Other results
Small et al., 2000 Phase I group (12) | 12 | 12 weeks | T-cell proliferative response to PA2024 increases from 0 to 4 to 8 weeks No other results presented separately for phase I group
Burch et al., 2000 (13) | 13 | 19.3 weeks | PSA 50% decline in 3 patients T-cell proliferative responses to PA2024, GM-CSF and PAP increase from time 0
Burch et al., 2004 (14) | 21 | 16.9 weeks | PSA decline 25-50% in 2 patients PSA decline to undetectable in 1 patient long term T-cell proliferative responses to PA2024 increased from time 0 Increases in antibodies to PA2024 and GM-CSF

#### Nonmetastatic Castrate-Resistant Prostate Cancer

One case series study included patients with nonmetastatic castrate-resistant prostate cancer.12 These patients are earlier in their stage of disease than those with metastatic disease. In general, these patients are identified with a rising PSA despite ADT, but they do not have metastases identified on imaging tests. Median time to progression in this set of patients was 29 weeks, which is indicative of their better prognosis than patients with metastases (Table 9). The case series design does not provide evidence as to the effectiveness of sipuleucel-T.

Table 9 Results of Case Series of Sipuleucel-T in Nonmetastatic Castrate-Resistant Prostate Cancer

Study (ref) | Sample size | Median time to progression | Other results
Small et al., 2000 Phase II group (12) | 19 | 29 weeks | No other results presented separately for phase II group

#### Nonmetastatic Hormone-Sensitive Prostate Cancer

Two published case series studies and one RCT reported in a conference abstract have enrolled patients with nonmetastatic hormone-sensitive prostate cancer.23, 34, 35 At this stage of disease, patients are generally asymptomatic, with the only sign of recurrent disease being a rising PSA level. Watchful waiting or ADT are recommended options at this stage of disease. The two case series studies were not intended to determine the efficacy of sipuleucel-T for this indication, but to determine whether a particular rate of PSA decline greater than 50 percent could be achieved. In one study, bevacizumab (Avastin®, Genentech) was added to the treatment regimen. Both studies did not reach their intended primary outcome, with fewer than expected patients achieving a 50 percent or greater reduction in PSA. Patients were also followed for progression of disease, defined in both studies a doubling of pretreatment PSA or PSA 4 ng/mL or greater if pretreatment PSA was 2 or less, or development of distant disease. Patients leaving the study for other treatments or withdrawing consent were considered progression end points. The median time to progression was 11.7 months and 11.2 months in the two studies (Table 10). A proportion of patients in each study had some reductions in PSA values, and one study showed a statistically significant increase in post-treatment PSA doubling time compared to pretreatment PSA doubling time. Because there are no control groups, and the validity of PSA as an adequate outcome measure for this treatment is unknown, these case series do not provide evidence of efficacy of sipuleucel-T for this indication.

Table 10 Results of Case Series of Sipuleucel-T in Nonmetastatic Hormone-Sensitive Prostate Cancer

Study (ref) | Sample size | Median time to progression | Other results
Beinart et al., 2005 (34) | 19 | 11.7 months (withdrawals for alternative treatment considered progression) | Negative result for primary outcome, zero patients with 50% reduction PSA 7/18 patients with 6-33% reduction of PSA No significant difference in pretreatment and post-treatment PSA doubling time
Rini et al., 2006 (35) | 22 | 11.2 months | Negative result for primary outcome, 1/21 patients with 50% reduction PSA 9/21 patients with any decrease in PSA Significant increase post-treatment PSA doubling time compared to pretreatment

One RCT for this indication has some information available. Details of the design, inclusion and exclusion criteria of the PROTECT clinical trial are described in clinicaltrials.gov, and a brief summary of preliminary results are available in a conference abstract.23, 36 The PROTECT trial enrolled patients with recurrent prostate cancer as demonstrated by a rising PSA after initial prostatectomy. They were to be given 3 months of hormonal therapy, then randomized to sipuleucel-T or placebo infusion, using the regimen of treatment as in the previously reviewed RCTs. The principal outcome was biochemical failure defined as a PSA 3 ng/mL or greater. A booster dose would be given at the time of biochemical failure. End points to be assessed beyond the time of biochemical failure would include time to distant metastasis, PSA doubling time, and overall survival.

The clinical outcomes of this trial are shown in Table 11. The principal outcome of biochemical failure was not significant. Median time to biochemical failure was 18 months in the sipuleucel-T treated group and 15.4 months in the placebo group. Distant failure is also in favor of sipuleucel-T but not statistically significant. At the time of the analysis only 16 percent of patients had attained this end point. There was a statistically significant increase in PSA doubling time in the treated group compared to placebo group. Given the lack of detailed information about this study, and the non-significant principal clinical end point assessed so far, this study does not provide adequate evidence of efficacy of sipuleucel-T for this indication.

Table 11 Results of a Randomized Trial of Sipuleucel-T in Nonmetastatic Hormone-Sensitive Prostate Cancer

Study (ref) | Sample size | Principal outcome: Median time to biochemical failure | p value | Other results
PROTECT, Beer et al., 2007 (23, 36) | 176 | Treatment: 18.0 months Control: 15.4 months hazard ratio=0.94 | >0.05 | Time to distant metastasis HR 0.73 (p>0.05), point estimate in favor of sipuleucel-T PSA doubling time increased in sipuleucel-T group compared to placebo group (p=0.046)

### Key Question 2a For off-label indications, what is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

Since none of the studies provide evidence of efficacy of sipuleucel-T for off-label indications, this question is moot.

### Key Question 3 What is the evidence regarding adverse events potentially attributable to the use of sipuleucel-T?

For several reasons, the issue of the adverse effects of sipuleucel-T is complex. For one, the patients are in an age group where comorbidities are common. As patients are followed for a survival end point, as disease progresses it would become increasingly difficult to attribute any particular event to the patients’ existing comorbidities, progressive cancer, sipuleucel-T, or other subsequent treatments. In all of the randomized clinical trials, after progression of prostate cancer (in IMPACT) or after 16 weeks (in D9901 and D9902A), adverse events, with the exception of cerebrovascular events, were only collected if they were thought by the investigators to be related to sipuleucel-T treatment. Since the studies became unblinded at the time of disease progression, such a judgment of causality could be biased.

The control groups of the randomized clinical trials did not receive a truly inert placebo. They were subjected to leukapheresis procedures and received an infusion of cultured but untreated cells. Thus any adverse effects caused by procedures in common between the treated and placebo groups might be balanced in the two groups. In the usual clinical trial with an inert placebo, an equal incidence of an adverse event in active and placebo groups implies that the event is due to inherent baseline risk, natural history, or psychological effects. This conclusion should not be made in these clinical trials, particularly for types of events that are suspected or known to be caused by infusions. If, for example, contaminated infusions cause an equal incidence of bacterial infection in both sipuleucel-T and placebo groups, it should not be concluded that sipuleucel-T does not cause bacterial infection.

In addition, after progression a large proportion of placebo-treated patients received frozen sipuleucel-T salvage treatment. We could not locate reports of the adverse events associated with frozen salvage treatment. It is unknown whether the potential risks of standard sipuleucel-T may occur with frozen sipuleucel-T salvage product. In addition, as reported previously, many patients in both groups received chemotherapy. Given these multiple confounding effects, it is very difficult to tell if events occurring distant in time to the initial treatment with sipuleucel-T or placebo can accurately be attributed to sipuleucel-T.

Because the studies of sipuleucel-T that enrolled patients for off-label indications were early studies that used different dosages and treatment protocols than the randomized trials, and each of the three randomized trials for labeled indications is relatively small, this report uses a pooled analysis of all the randomized trials for the analysis of adverse events. This pooled safety analysis is reported in an FDA clinical review.17 In addition to the three RCTs for the FDA-labeled indication (IMPACT, D9901, D9902A), the PROTECT trial for an off-label indication is included. The number of patients included in the pooled safety analysis is 601 patients treated with sipuleucel-T and 303 placebo-treated patients, of which 176 are from the PROTECT trial (allocated 2:1 sipuleucel-T:placebo). The pooled analysis provides the largest sample size and the best opportunity of detecting adverse events. The initial treatment protocol for administering sipuleucel-T was identical for all trials.

However, the FDA safety review in this document is a long detailed section over 40 pages in length with numerous tables, case reports, and unquantified descriptions of analysis. We will focus this presentation on some of the issues analyzed in the review we judged to be relevant: 1) deaths occurring proximate in time to treatment; 2) nonfatal serious adverse events; 3) cerebrovascular events; 4) infections; and 5) infusion-related adverse events. Brief descriptions and summaries of other safety analyses are provided in Appendix Table A6.

Using the questions proposed to evaluate the quality of reporting harms based on the McMaster Quality Assessment Scale for Harms, based on the description of adverse events reporting from the protocol document for the IMPACT trial and the FDA Clinical Review, we judged that all 6 questions could be answered affirmatively and thus the adverse event reporting in this document was of good quality.

#### Deaths Occurring Proximate to Treatment

Four deaths occurred within 30 days after receiving infusions, 3 (0.5 percent) in the sipuleucel-T group and 1 (0.3 percent) in the placebo group. One subject in the sipuleucel-T group appears to have had a possible transient cerebrovascular event on the day of the third infusion, and had a fatal stroke 2 weeks after the third infusion. The other 3 deaths all appear to have been due to cancer progression.

#### Nonfatal Serious Adverse Events

A serious adverse event is defined as any adverse drug experience that results in any of the following outcomes; death, a life-threatening experience, inpatient hospitalization or prolongation of existing hospitalization, a persistent or significant disability/incapacity, or the judgment of the investigator that medical or surgical intervention might be needed to prevent one of these outcomes.

Table 12 shows the incidence of serious adverse events classified according to preferred terms using the Medical Dictionary for Regulatory Activities (MedDRA) classification system for coding adverse events. The overall incidence is similar between sipuleucel-T and placebo-treated groups (24.0 percent versus 25.1 percent). Small numbers preclude the ability to make strong statistical conclusions regarding the risk of any single type of event. Events that occurred in more than 1 percent of subjects and more often in the treated group than the placebo group included pyrexia, spinal cord compression, chills, and dyspnea.

These adverse events were also recategorized by system organ class (data not shown). Adverse events that were at least 1 percent more frequent in the sipuleucel-T group than the placebo group included nervous system disorders, general disorders and administration site conditions, and musculoskeletal and connective tissue disorders. Most of the nervous system disorders were cerebrovascular events and transient ischemic attacks. These were analyzed in another analysis to be presented shortly. With the exception of pyrexia and chills, most of these adverse events occurred more than 14 days after the last treatment infusion. Thus the causality of the event to treatment is uncertain. Pyrexia and chills are symptoms consistent with an acute reaction to infusion, and will be analyzed again in another separate analysis.

In another similar analysis using the National Cancer Institute Common Toxicity Criteria for Adverse Events, adverse events were graded on a 1 to 5 scale, with 5 being the most serious adverse event of fatality. The incidence of grade 3 to 5 (serious to fatal) adverse events was similar between sipuleucel-T and placebo groups (30.9 percent and 32.0 percent, respectively).

#### Cerebrovascular Events

Due to a safety analysis done during a prior review of sipuleucel-T in 2007, specific attention was applied to the incidence of cerebrovascular events (CVE). As a condition of approval, FDA has required that the incidence of CVEs be assessed in a post-marketing surveillance study. Table 13 summarizes the incidences and types of CVEs from the 4 randomized trials. Overall, a higher incidence of CVEs occurred in the sipuleucel-T-treated group than the placebo group. The small number of specific types of events makes it difficult to make conclusions about these events. An exploration of the underlying risk factors for CVE showed several slight imbalances between groups in the risk factors for CVE, with the placebo group having lower prevalence of several risk factors for CVE, such as lower age, lower prevalence of hypertension, lower composite prevalence of several cardiovascular risk factors, and lower prevalence of prior cerebrovascular event. Thus although the incidence of CVE was higher in the sipuleucel-T group, the difference was small (absolute risk difference 1.1 percent) and it is possible that underlying risk factors could explain this difference. CVE-associated deaths were also compared. There were slightly more fatal CVEs in the sipuleucel-T group (1.4 percent versus 0.7 percent). The difference is too small to make definitive conclusions.

Table 12 Serious Nonfatal Adverse Events (SAE) Classified by Preferred Term and Treatment Group

Serious Adverse Event | Sipuleucel-T n=601 n (%) | Placebo n=303 n (%)
Any subject reporting SAE | 144 (24.0) | 76 (25.1)
Cerebrovascular Accident | 11 (1.8) | 6 (2.0)
Pyrexia | 10 (1.7) | 1 (0.3)
Spinal Cord Compression | 7 (1.2) | 2 (0.7)
Chills | 6 (1.0) | 0
Dehydration | 6 (1.0) | 4 (1.3)
Dyspnea | 6 (1.0) | 1 (0.3)
Atrial Fibrillation | 5 (0.8) | 4 (1.3)
Transient Ischemic Attack | 5 (0.8) | 1 (0.3)
Back Pain | 4 (0.7) | 6 (0.7)
Catheter Sepsis | 4 (0.7) | 4 (0.4)
Hematuria | 4 (0.7) | 8 (0.9)
Nausea | 4 (0.7) | 6 (0.7)
Prostate Cancer Metastatic | 4 (0.7) | 8 (0.9)
Pulmonary Embolism | 4 (0.7) | 6 (0.7)
Staphylococcal Bacteremia | 4 (0.7) | 0
Anemia | 3 (0.5) | 2 (0.7)
Arthralgia | 3 (0.5) | 0
Cardiac Failure Congestive | 3 (0.5) | 3 (1.0)
Osteoarthritis | 3 (0.5) | 1 (0.3)
Pneumonia | 3 (0.5) | 3 (1.0)
Sepsis | 3 (0.5) | 3 (1.0)
Staphylococcal Sepsis | 3 (0.5) | 0
Subdural hematoma | 3 (0.5) | 1 (0.3)
Syncope | 3 (0.5) | 1 (0.3)
Acute Myocardial Infarction | 2 (0.3) | 0
Asthenia | 2 (0.3) | 1 (0.3)
Atrial Flutter | 2 (0.3) | 0
Bacteremia | 2 (0.3) | 1 (0.3)
Brain Mass | 2 (0.3) | 0
Catheter Bacteremia | 2 (0.3) | 0
Cerebral Infarction | 2 (0.3) | 0
Cervical Vertebral fracture | 2 (0.3) | 0
Chest Pain | 2 (0.3) | 0
Chest Wall Pain | 2 (0.3) | 0
Chromic Myelomonocytic Leukemia | 2 (0.3) | 0
Coronary Artery Disease | 2 (0.3) | 2 (0.7)
Disseminated Intravascular Coagulation | 2 (0.3) | 1 (0.3)
Gait Disturbance | 2 (0.3) | 0
Gastrointestinal Hemorrhage | 2 (0.3) | 0
Hemorrhage Intracranial | 2 (0.3) | 0
Hyperhidrosis | 2 (0.3) | 0
Hypertension | 2 (0.3) | 0
Hypoxia | 2 (0.3) | 0
Infusion-Related Reaction | 2 (0.3) | 0
Intervertebral Disc Protrusion | 2 (0.3) | 0
Intestinal Obstruction | 2 (0.3) | 1 (0.3)
Lacunar Infarction | 2 (0.3) | 0
Metastasis to Spine | 2 (0.3) | 0
Muscular weakness | 2 (0.3) | 1 (0.3)
Myocardial Infarction | 2 (0.3) | 1 (0.3)
Myocardial Ischemia | 2 (0.3) | 1 (0.3)
Pain in Extremity | 2 (0.3) | 0
Pathological Fracture | 2 (0.3) | 1 (0.3)
Pleural Effusion | 2 (0.3) | 1 (0.3)
Tachycardia | 2 (0.3) | 0
Urinary Tract Retention | 2 (0.3) | 4 (1.3)
Urinary Tract Retention | 2 (0.3) | 1 (0.3)

Bold print indicates a higher incidence in sipuleucel-T treated group than in placebo-treated group

Table 13 Summary of Incidence and Characteristics of Cerebrovascular Events

| Sipuleucel-T n=601 n (%) | Placebo n=303 n (%)
Cerebrovascular event incidence (including TIA) | 24 (4.0 %) | 9 (2.9 %)
Ischemic stroke | 16 (2.7%) | 8 (2.6%)
Hemorrhagic stroke | 4 (0.7%) | 1 (0.3%)
Unknown stroke | 4 (0.7%) | 0
Transient ischemic attack (TIA) | 5 (0.8%) | 1 (0.3%)

#### Infections

Due to the manufacturing and infusion process of sipuleucel-T, there is the possibility of infections due to the product or the venous catheters need to infuse the treatment. The placebo group, because it also underwent leukapheresis and infusion, does not represent a “background” rate of infection of a true untreated control group. Infections specifically identified as catheter-related infections should be viewed as the risk of infection related to treatment regardless of treatment group. Infections occurring proximate in time to leukapheresis and infusion might be related to treatment, but attribution is difficult.

Overall, similar percentages of subjects developed infection adverse events, 27.5 percent in the sipuleucel-T group and 27.7 percent in the placebo group (Table 14). These overall incidences of infection in either group may not be related to sipuleucel-T or placebo treatment. However, 15.3 percent and 14.5 percent of subjects in each group developed infections within one week of their final infusion. Some of these infections in either group may possibly be related to leukapheresis and/or infusion. Infections designated as catheter-related occurred overall in 3 percent of subjects (sipuleucel-T group 3.2 percent, placebo group 2.6 percent) and would not have occurred but for treatment-related procedures. Infections occurring late in the clinical trials (after 16 weeks or disease progression) are not reported unless attributed to sipuleucel-T, according to the protocol for reporting adverse events.

Table 14 Summary of Various Incidence Rates of Infections

Infection outcome | Sipuleucel-T n=601 n (%) | Placebo n=303 n (%)
Infection adverse event during study | 165 (27.5%) | 84 (27.7%)
Infection events within one week of final infusion | NR (15.3%) | NR (14.5%)
Infection event grade 3 or higher severity | 30 (5%) | 10 (3.3%)
Catheter-related infection | 19 (3.2%) | 8 (2.6%)

Finally, it is noted in this section of the FDA review that sterility tests are done on the infusion product but results are not available until some days after infusion. Three patients in the IMPACT study received products that were found to be contaminated; two of three developed infection adverse events, one which was grade 4 severity. Thus it appears that sipuleucel-T treatment is associated with increased risk of infections, and that there is a possibility of product contamination leading to infection.

#### Infusion Reaction Adverse Events

Exploration of incidence of commonly reported adverse events of usually low severity led to an analysis of incidence of adverse events which are commonly associated with infusion reactions. An analysis was performed using terms that are included in the National Cancer Institute Common Terminology Criteria for Adverse Events for infusion reaction syndrome.

Table 15 shows the incidence of overall infusion reaction-related adverse events and each separate term, for adverse events occurring within 1 day of infusion. Overall, the incidence of any infusion reaction adverse event was much higher in the sipuleucel-T treated group than the placebo group, 71.4 percent versus 28.7 percent. In terms of severe infusion reactions rated grade 3 severity, these occurred in 21 subjects in the sipuleucel-T group and none in the placebo group. Seven subjects in the sipuleucel-T group were hospitalized for management of an acute infusion reaction.

#### Adverse Event Interactions

There is a brief text description in the FDA review describing analyses regarding associations of adverse events with product parameters and patient characteristics. Very little quantitative data is presented in this section, so results will simply be paraphrased from the FDA review. There seemed to be no association between adverse events and the product parameters of total nucleated cell count, CD54 cell count, and CD54 upregulation. There was slightly higher incidence of adverse events associated with infusion reactions in subjects younger than 65 years old. None of the differences appeared to be clinically important. There were not enough African American subjects in the study for meaningful analysis of possible racial interactions.

#### Summary of Adverse Effects Review

Despite the presence of confounding issues relating to the study design of the randomized clinical trials, there are a few solid conclusions that can be reached. Sipuleucel-T infusions can cause symptoms consistent with an infusion reaction, usually within 1 day of infusion, of greater frequency than a placebo infusion. Thus the causality of the activated product causing such reactions is quite certain. These infusion reactions were occasionally severe; 21 out of 601 patients had grade 3 severity infusion reactions, and 7 required hospitalization.

Sipuleucel-T is also associated with infections, probably in relation to leukapheresis and infusion procedures. Catheter-related infections are attributable to sipuleucel-T treatment. Some infections proximate in time to infusion are possibly related to sipuleucel-T treatment. Attribution is difficult because the control groups in the RCTs also underwent leukapheresis and infusion procedures. Contaminated infusion product has been documented.

For all other serious types of adverse events, it is unclear whether there is an association with sipuleucel-T treatment. CVEs were a particular focus of attention, and although rates were slightly higher, it is not possible with the data available to determine causality.

No associations with product parameters or interactions with patient characteristics were identified.

Table 15 Incidence of Infusion Reaction Adverse Events Within 1 Day of Infusion

Adverse Event by Preferred Term | Sipuleucel-T n=601 n (%) | Placebo n=303 n (%)
Any adverse event | 428 (71.4) | 87 (28.7)
Chills | 300 (49.9) | 16 (5.3)
Pyrexia | 146 (24.3) | 6 (2.0)
Fatigue | 126 (21.0) | 43 (14.2)
Headache | 72 (12.0) | 6 (2.0)
Nausea | 71 (11.8) | 7 (2.3)
Myalgia | 47 (7.8) | 7 (2.3)
Arthralgia | 33 (5.5) | 10 (3.3)
Hypertension | 29 (4.8) | 2 (0.7)
Asthenia | 28 (4.7) | 10 (3.3)
Dizziness | 25 (4.2) | 6 (2.0)
Hyperhidrosis | 21 (3.5) | 0
Malaise | 17 (2.8) | 4 (1.3)
Dyspnea | 16 (2.7) | 1 (0.3)
Flushing | 13 (2.2) | 7 (2.3)
Hypotension | 11 (1.8) | 1 (0.3)
Rash | 8 (1.3) | 2 (0.7)
Hot Flush | 7 (1.2) | 4 (1.3)
Lethargy | 7 (1.2) | 0
Cough | 6 (1.0) | 3 (1.0)
Hypoxia | 5 (0.8) | 0
Urticaria | 4 (0.7) | 0
Feeling Hot | 3 (0.5) | 0
Tachycardia | 3 (0.5) | 0
Bronchospasm | 2 (0.3) | 0
Pruritus | 2 (0.3) | 2 (0.7)
Any grade 3 infusion reaction | 21 (3.5) | 0
Hospitalization for infusion reaction serious adverse events | 7 (1.2) | 0