# Methods

As detailed below, certain aspects of Methods and Materials may vary to satisfy requirements of each question. However, the Methods are generally applicable to all Key Questions, including Methods of the Review, Evidence Tables, Identifying Additional Studies, and Assessing Study Quality.

## Database Search Strategies

The following electronic databases were searched for citations (search strategy can be found in Appendix C).

- MEDLINE® (inception [1948] through July 13, 2010)
- EMBASE® (inception [1974] through July 13, 2010)
- Cochrane Controlled Trials Register (no date restriction)

The search was limited to English-language references. Because the review of on-label uses primarily focused on randomized, controlled trials (RCTs), the Cochrane Handbook search strategy for controlled trials was applied.16

The searches resulted in 47 unique citations. In addition to the electronic database searches, we examined the bibliographies of all retrieved articles for citations to any RCT or case series that was missed in the database searches. We searched clinicaltrials.gov and fda.gov for information on any clinical trials of sipuleucel-T. We performed online searches of selected conference proceedings and abstracts.

## Patient Populations

The populations of interest are definable categories of patients with prostate cancer for which sipuleucel-T has been used to treat prostate cancer. The FDA-labeled indication for sipuleucel-T is patients with asymptomatic or minimally symptomatic patients with castrate-resistant (hormone-refractory) prostate cancer.

Off-label indications can only be surmised by the particular inclusion and exclusion criteria of the particular studies we have reviewed. Some early studies of sipuleucel-T included patients similar to the FDA-labeled indication, but without the requirement of no or minimal symptoms. However, based on the high Eastern Cooperative Oncology Group (ECOG) performance scores reported for these patients, they appear to be very similar to patients meeting FDA-labeled indications.

Other groups of patients enrolled in studies that could be said to describe an indication for use of sipuleucel-T include patients with progressive nonmetastatic castrate-resistant prostate cancer and patients with recurrent nonmetastatic hormone-sensitive prostate cancer. The former group represents a generally earlier time in the sequence of cancer progression than the FDA-labeled indication. The latter group represents the earliest time of cancer recurrence after failure of primary treatment.

## Interventions

The intervention of interest for all key questions is the use of sipuleucel-T for the treatment of prostate cancer. In the randomized trials of sipuleucel-T, no other treatment was given until disease progression. At that point in time, patients were then treated at the discretion of their own physician. Thus, these trials represent a treatment strategy of sipuleucel-T and deferral of other treatment until disease progression, then as indicated in the judgment of the treating physician.

## Comparators

Comparators are the standard treatment for patients with prostate cancer at the particular stage of disease or indication at which sipuleucel-T was administered in the studies. For the RCTs, the comparator treatment strategy is explicit. Placebo sipuleucel-T infusions, which consist of infusion of untreated autologous cells, followed by observation until disease progression represent a strategy of watchful waiting and deferred treatment, at least until objective disease progression, then additional treatment at the discretion of the patient and physician.

For the case series studies, the implied comparator is watchful waiting. For the patient indications for which sipuleucel-T has been given, this is a reasonable comparator, although active treatment is an option.

## Outcomes of Interest

### Benefits

Outcomes of interest include overall survival, quality of life, and cancer progression. Because of the novel nature of this treatment, it is not known if commonly used surrogate measures of outcome in prostate cancer such as change in PSA levels or change in PSA doubling time correlate with more definitive outcome measures. The validity of such surrogate measures in the context of sipuleucel-T treatment would need to be established in prospective studies. Measures of immunologic function or immunologic reaction to sipuleucel-T are physiologic tests, not health outcomes, and we did not routinely abstract these data as a relevant health outcome.

### Harms

Adverse effects occurring during or after treatment may be attributable to sipuleucel-T based on biologic plausibility, temporal association to sipuleucel-T administration, or a formal comparison of potentially attributable events in the treated group compared to a control group followed with equal intensity for the adverse events.

## Study Selection Criteria

Studies were selected to address the Key Questions identified for this technology assessment. One reviewer screened titles and abstracts of identified studies using the following eligibility criteria. If this could not be done satisfactorily from the title and abstract, we obtained a full-text version for assessment. Articles published in a language other than English were not included in this technology assessment.

### Key Question 1

We abstracted data from case series and randomized clinical trials that utilized sipuleucel-T therapy in patients meeting the FDA-approved indication that measured a health outcome of interest.

### Key Question 2

We abstracted data from any type of study enrolling a series of patients that utilized sipuleucel-T therapy for a definable indication of patients with prostate cancer, not meeting the FDA-approved indication that measured a health outcome of interest.

### Key Question 3

We originally planned to abstract data from any type of study enrolling a series of patients that reported the incidence of adverse effects in patients undergoing treatment with sipuleucel-T, including studies where analyses attempted to determine associations and causation of the adverse effects. However, most case series studies used treatment protocols different than the current FDA-labeled indication, and the preparation of sipuleucel-T may have varied from the current product.

To summarize the information with the largest data set using current treatment protocols, we abstracted data from the FDA Clinical Review of sipuleucel-T.17 This Clinical Review pooled data from all four RCTs that have investigated the treatment. Adverse effects were assessed in very close to uniform methods across all four studies using established methods for measuring adverse effects.

## Data Analysis and Presentation

Electronic search results were stored in a ProCite® database and the number of references retrieved and included in the technology assessment was documented. Using the final study selection criteria for screening titles and abstracts, a single reviewer marked each citation as 1) eligible for review as a full-text article, 2) ineligible for full-text review.

Detailed records of the results of this evaluation were kept for each paper retrieved in full text, including the reason for exclusion of each excluded study. The following data elements of primary studies were abstracted as available from the articles meeting all selection criteria.

a. General information: title, authors, source, year of publication, duplicate publications, setting, funding
b. Trial characteristics: method of randomization, concealment of allocation, blinding of patients and clinicians
c. Patients: sampling, exclusion criteria, sample size, baseline characteristics, similarity of groups at baseline, diagnostic criteria, withdrawals, losses to follow up
d. Interventions: dose, dosing regimen, duration, route, co-medications with dose, timing
e. Analytical methods
f. Outcomes: outcomes as specified above

## Evidence Tables

We created templates for evidence tables in Microsoft Word®. One reviewer performed primary data abstraction of all data elements into the evidence tables, and a second reviewer performed accuracy checks on the evidence tables.

## Assessment of Study Quality

The quality (internal validity) of included studies (RCTs and other comparative designs) was assessed on the basis of the general approach to grading evidence developed by the U.S. Preventive Services Task Force.18 Quality criteria were as follows:

a. Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups
b. Maintenance of comparable groups (includes attrition, crossovers, adherence contamination)
c. Important differential loss to follow-up or overall high loss to follow-up
d. Measurements: equal, reliable, and valid (includes masking of outcome assessment)
e. Clear definition of interventions
f. All important outcomes considered
g. Analysis: adjustment for potential confounders, intention-to-treat analysis
h. The rating of intervention studies encompasses the three quality categories described here:

Studies were rated as “good” if they met all criteria: Comparable groups were assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; all important outcomes are considered; and appropriate attention was given to confounders in analysis. In addition, for RCTs, intention-to-treat analysis was used.

Studies were rated as “fair” if any or all of the following problems occurred, without the fatal flaws noted in the “poor” category below: In general, comparable groups were assembled initially but some question remained as to whether some (although not major) differences occurred with follow-up; measurement instruments were acceptable (although not the best) and generally applied equally; some but not all important outcomes were considered; and some but not all potential confounders were accounted for. In addition, for RCTs, intention-to-treat analysis was used.

Studies were graded “poor” if any of the following fatal flaws existed: Groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments was used or not applied at all equally among groups (including not masking outcome assessment); and key confounders were given little or no attention. For RCTs, intention-to-treat analysis was lacking.

For studies of adverse effects, there are no validated standard tools to assess either reporting bias or completeness for harms. Consequently, reporting was assessed using an empirically derived set of questions informed by the McMaster Quality Assessment Scale for Harms (McHarm) and the Agency for Healthcare Research and Quality (AHRQ) draft Methods Manual guidance.19, 20

▪ Is there an explanation of how harms were identified?
▪ Was a standardized or validated instrument or scale used?
▪ Was ascertainment similar and complete in all study groups?
▪ Was a measure of severity reported?
▪ Were harms attributed to the study intervention likely causally associated?
▪ Were the number and type of harmful events reported separately for study groups?

## Data Synthesis

This evidence review did not incorporate quantitative data synthesis using meta-analysis. Studies for the same indication are presented and discussed together, and evaluated on the basis of individual study quality for potential biases and errors. Consistency of the findings is evaluated qualitatively.

## Rating the Body of Evidence

The system used for rating the strength of the overall body of evidence was developed by AHRQ for the EPC Methods Guide, based on a system developed by the GRADE Working Group.21, 22 This system explicitly addresses the following domains: risk of bias, consistency, directness and precision. Grade of evidence strength was classified into the following four categories:

▪ High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
▪ Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
▪ Low: Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
▪ Insufficient: Evidence is either unavailable or does not permit estimation of an effect.