# Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (Contract Number: HHSA 290 2007 10058 I). The specific questions to be addressed are described at the end of the Introduction.

## Epidemiology of Prostate Cancer

Prostate cancer is the most common malignancy in men and a common cause of cancer mortality. The 2010 American Cancer Society estimates for prostate cancer in the U.S. are approximately 217, 730 new cases of prostate cancer and 32,050 prostate cancer deaths.1 Approximately one man in six will be diagnosed with prostate cancer during his lifetime. More than 2 million men in the U.S. who have been diagnosed with prostate cancer at some point are still alive today.

Initial treatment strategies for localized prostate cancer include active surveillance, radiation therapy, brachytherapy, and surgery.2 After initial treatment, patients are monitored for recurrence by measuring prostate-specific antigen (PSA) levels on a regular basis and imaging tests, if a distant metastasis is clinically suspected. If cancer recurs, and imaging workup indicates the presence or high suspicion of metastasis, androgen-deprivation therapy (ADT) is the standard therapy. ADT in the form of various medications or bilateral orchiectomy are equally effective. Effective ADT will produce a decrease in serum PSA levels, pain relief, and regression of soft tissue metastases. However, ADT does not permanently suppress the progression of cancer, and eventually most patients will experience a rise in PSA levels, followed by development and/or progression of metastases. Such a state of advanced cancer is called castrate-resistant prostate cancer.

### Castrate-Resistant Prostate Cancer

Treatment recommendations for castrate-resistant prostate cancer according to the most current National Comprehensive Cancer Network (NCCN) guidelines, depend on whether metastatic disease is present or not.2 In the absence of metastases, observation, enrollment in a clinical trial, antiandrogen withdrawal, or secondary ADT are among the mentioned options. In the presence of metastases, sipuleucel-T (Provenge®, Dendreon Corporation), docetaxel (Taxotere®, Sanofi Aventis) chemotherapy, mitoxantrone (Novantrone®, Serono Laboratories) and corticosteroids, secondary ADT, and palliative radiation therapy for symptomatic bone metastases are the listed options. Secondary ADT is commonly used prior to consideration for chemotherapy. Docetaxel has been demonstrated to prolong survival in randomized clinical trials.

However, even with treatment, the prognosis of castrate-resistant prostate cancer is not very good, with median survival generally less than two years. Various characteristics of patients have been correlated with survival in several studies. According to a prognostic model developed by Halabi and co-workers, longer survival was predicted by a Gleason score less than 8, better performance status, lower levels of baseline PSA, lactate dehydrogenase (LDH), and alkaline phosphatase, a higher hemoglobin level, and absence of visceral disease.3 In this study sample, largely drawn from clinical trials before docetaxel chemotherapy was used in patients with prostate cancer, the lowest to highest predicted risk quartiles had actual median survivals of 7.5, 13.4, 18.9, and 27.2 months, respectively. In another prognostic model by Smaletz and colleagues, longer survival was associated with better performance status, lower levels of alkaline phosphatase and LDH, and higher levels of hemoglobin and albumin.4 PSA levels and age were not associated with survival, but were included in the prognostic model. Finally, in a prognostic model based on the clinical trial that led to U.S. Food and Drug Administration (FDA) approval of docetaxel for castrate-resistant prostate cancer, in addition to all the variables included in the predictive model of Halabi et al., longer survival was associated with absence of pain at baseline, fewer metastatic sites, longer PSA doubling time, and PSA-only type of progression (versus measurable disease or bone scan progression).5

Prior to the approval of sipuleucel-T, the only treatment demonstrated to have improved survival of castrate-resistant prostate cancer in randomized clinical trials was docetaxel. In the clinical trial that led to FDA approval for this indication, 1,006 men were randomly assigned to either mitoxantrone plus prednisone or 2 different regimens of docetaxel plus prednisone (i.e., every 3 weeks or every week).6 The comparator regimen in this study, mitoxantrone, had previously been demonstrated to have palliative effects for prostate cancer symptoms, but had not demonstrated improvement in survival. Compared with mitoxantrone, the group given docetaxel every 3 weeks had a hazard ratio for death of 0.76 (95 percent confidence interval [CI]: 0.62–0.94). The median survival was 16.5 months in the mitoxantrone group compared to 18.9 months in the group given docetaxel every 3 weeks, a difference of 2.4 months. The group given docetaxel every 3 weeks also had greater reductions in pain and greater percent improvement in measures of quality of life. The group given weekly docetaxel generally had outcomes intermediate between the other two groups, with some of the outcomes not being statistically significantly different than the mitoxantrone group. An updated survival analysis of this trial shows similar results; the group given docetaxel every 3 weeks has a median survival of 19.2 months, versus 16.3 months in the mitoxantrone group.7

In another study by Petrylak and colleagues, 770 men were randomized to either estramustine plus docetaxel every 3 weeks or mitoxantrone plus prednisone every 3 weeks.8 The overall median survival was 15.6 months in the mitoxantrone group and 17.5 months in the docetaxel group (p=0.02), a difference of 1.9 months, and the corresponding hazard ratio for death was 0.80 (95 percent CI: 0.67–0.97).

Like many chemotherapy agents, docetaxel has several adverse effects, the most common ones being hair loss, nausea and vomiting, fatigue, sensory neuropathy, and neutropenia. In the FDA pivotal trial, these particular events all occurred at a frequency of 30 percent or greater in the group given docetaxel every 3 weeks.

Although docetaxel is approved for castrate-resistant prostate cancer as is sipuleucel-T, their labeled indications are not identical. One major difference is that the patients must not necessarily be asymptomatic or minimally symptomatic. The clinical trials of docetaxel enrolled a high proportion of patients with baseline pain (45 percent with a minimum score or 2 or more on the Present Pain Intensity Scale in the FDA pivotal trial, 36 percent in the trial of Petrylak et al.8). The results of the FDA pivotal trial stratified by baseline pain appear to produce qualitatively similar relative amounts of benefit in both patients with and without pain. Some investigators believe this causes many practitioners to defer docetaxel therapy until symptoms develop or there is a rapid rise in PSA levels, in order to balance the benefit of therapy with the desire to defer toxicity.9 The NCCN guidelines do not address the issue of the timing of chemotherapy. Some articles have suggested that because of the longer survival of pain-free patients relative to patients with baseline pain, the benefit of docetaxel in pain-free patients may translate to a longer survival benefit, and thus consideration should be given to giving docetaxel before symptoms develop.9

## Sipuleucel-T

The biologic premise of sipuleucel-T is that the treatment stimulates the patient’s own immune system to target prostate cancer cells. T-cells that are sensitized to specific antigens present on prostate cancer cells may be able to destroy or prevent proliferation of cancer cells.

Sipuleucel-T is manufactured from the patient’s own white cells, which are collected from a procedure called leukapheresis.10 The leukapheresis procedure essentially filters out the cells of interest and retransfuses the remainder back into the patient. The collected cells, which are mixture of peripheral blood mononuclear cells including antigen-presenting cells, T-cells,, and B-cells, are then cultured with a protein called PA2024. PA2024 is a recombinant protein consisting of human prostatic acid phosphatase (PAP) fused with granulocyte-macrophage colony stimulating factor (GM-CSF). The interaction of the antigen-presenting cells with PA2024 is considered the essential process that stimulates the immune system. Antigen-presenting cells take in antigens and then “present” them to T-cells throughout the body, which should then react to cells with PAP such as prostate cancer cells as foreign substances. The entire process from leukapheresis to infusion of sipuleucel-T is approximately 3 days. Sipuleucel-T must be administered within 18 hours of manufacture. The dosing regimen for the FDA-labeled indication is 3 doses, each 2 weeks apart, for a total treatment period of 4 weeks.

Because sipuleucel-T is made from a patient’s own white cells, particular aspects about the treatment should be noted. The cellular composition of each dose is dependent on the composition of cells obtained during leukapheresis, which can vary between patients and in a single patient between leukapheresis sessions. According to the published report of the pivotal FDA trial of sipuleucel-T, each dose contained a minimum of 40 million cells expressing the co-stimulatory molecule CD54.^11^ Cells expressing CD54 are considered the active ingredient of the treatment. However, the variation between doses in the number of cells expressing CD54 may be great. In an early study of sipuleucel-T by Small and colleagues, although the current manufacturing process may vary from that study, the median number of CD54 cells in each dose was 278 million cells, with a range between 18.6 and 1,276 million, more than a 50-fold difference.12 The minimum cell requirements for a satisfactory dose of sipuleucel-T may require the patient to undergo additional leukapheresis procedures.

### Immunologic Response to Sipuleucel-T Treatment

In the studies of sipuleucel-T to be reported later in this technology assessment, various types of immunologic tests were performed on the cells of patients treated with sipuleucel-T.12–14 The types of findings observed will be summarized in this section of the technology assessment, as they relate to the possible mechanisms and biology of the treatment, and are not themselves clinical outcomes. Some of these observations may provide clinical value as predictors of treatment success or patient prognosis.

T-cells of patients who have been treated with sipuleucel-T will replicate when exposed to PA2024, PAP, and GM-CSF. A T-cell proliferation assay can measure the degree to which T-cells will replicate in response to exposure to specific types of antigens, which is considered a measure of successful induction of immunity to that particular substance. All the human studies of sipuleucel-T have demonstrated that there is a greater proliferation of T-cells in response to PA2024, PAP, and GM-CSF after treatment than before treatment. Such studies have also tested proliferation to control substances and to common influenza antigens, and demonstrated that the T-cell proliferation response to these antigens is explained by exposure to sipuleucel-T. Antibodies to PA2024, PAP, and GM-CSF can be detected in a greater proportion of patients after treatment than before treatment, as well.

A process that has been proposed as a measure of the potency of sipuleucel-T is called CD54 upregulation.10 During the manufacture of sipuleucel-T, the number of CD54 molecules expressed on the antigen-presenting cells increases. The amount of this increase can be quantified using specific assays. The quantity of this increase varies between patients, and varies depending on prior exposure to sipuleucel-T. Greater CD54 upregulation is observed after the first dose of treatment, indicating that antigen-presenting cells respond differently to culture in PA2024 after an initial systemic exposure to sipuleucel-T. The potential role of CD54 upregulation as a predictor of patient response will be discussed more thoroughly in a later section of this technology assessment.

### U.S. Food and Drug Administration (FDA) Approval and Prescribing Information

In April 2010, sipuleucel-T was approved by the FDA. The indication approved was for the treatment of asymptomatic or minimally symptomatic castrate-resistant (hormone-refractory) prostate cancer. There is some notable information in the full prescribing information document that will not be covered in this technology assessment, but should be mentioned because this information will probably affect the clinical use of sipuleucel-T.15 Most notably, there are no contraindications listed. Warnings and precautions are stated regarding the possibility of acute infusion reactions, the risk of transmissible infectious disease to health care professionals handling the product, and that the prior, concomitant, and post-treatment use of chemotherapy and immunosuppressive medications has not been studied. It is additionally stated that the concurrent use of immunosuppressive agents may alter the efficacy and/or safety of sipuleucel-T, and that “patients should be carefully evaluated to determine whether it is appropriate to reduce or discontinue immunosuppressive agents prior to treatment…”

### Practice Guidelines

Sipuleucel-T is included as a category I recommended treatment for patients meeting the FDA-labeled indication in the most recent version of the NCCN practice guidelines for prostate cancer.2 The guideline mentions that the treatment is only recommended for patients who have good performance level, estimated life expectancy greater than 6 months, no visceral disease, and no or minimal symptoms. The guideline notes that markers of benefit of therapy are usually not seen and the benefit to the individual patient cannot be currently ascertained.

## Key Questions to be Addressed by this Technology Assessment

Key Question 1. What is the evidence regarding the clinical outcomes of sipuleucel-T for its FDA-approved indication; asymptomatic or minimally symptomatic metastatic androgen-independent prostate cancer?

Question 1a. What is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

Key Question 2. What is the level of evidence and summary of evidence for off-label indications for sipuleucel-T?

Question 2a. For off-label indications, what is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

Key Question 3. What is the evidence regarding adverse events potentially attributable to the use of sipuleucel-T?