# Search Strategy

The following electronic databases were searched for citations.

- MEDLINE® (inception [1948] through July 13, 2010)
- EMBASE® (inception [1974] through July 13, 2010)
- Cochrane Controlled Trials Register (no date restriction)

The MEDLINE® search resulted in 190 unique citations many of which were news-type articles so the search was limited to the following document types: Clinical Trial, Meta-Analysis, Practice Guideline, Randomized Controlled Trial, Comparative Study, Controlled Clinical Trial, Multicenter Study and that resulted in 23 records. The EMBASE® search resulted in 361 citations and was limited to restrict to articles, which resulted in 86 records. The Cochrane search resulted in 3 new citations.

In addition to the electronic database searches, we also examined the documents available on the U.S. Food and Drug Administration’s website regarding the Dendreon submissions to the FDA for approval of this product. The bibliographies of all retrieved articles were also reviewed for citations to any RCT that was missed in the database searches. We did not systematically seek studies published in conference proceedings and abstracts.

MEDLINE search 7/13/10

1. provenge OR sipuleucel* OR Dendreon OR "APC-8015" = 87
2. (prostate OR prostatic) AND "dendritic cell*" = 115
3. 1 OR 2 = 190
4. 3 and Limits: Humans, Clinical Trial, Meta-Analysis, Practice Guideline, Randomized Controlled Trial, Comparative Study, Controlled Clinical Trial, Multicenter Study, English = 23
5. plus selective searching through the 187 from set 3 that weren’t in set 4.

EMBASE search 7/13/10

1. 'provenge'/exp OR sipuleucel* OR dendreon OR 'apc 8015'/exp AND [humans]/lim AND [embase]/lim (not MEDLINE) = 321
2. 'prostate'/exp OR prostatic AND ('dendritic cell'/exp OR 'dendritic cells'/exp) AND [humans]/lim AND [embase]/lim = 55
3. 1 OR 2 = 361
4. 3 AND 'article'/it = 86