# Appendix Figures

Appendix Figure B1 Sipuleucel-T treatment hazard ratios according to subgroups from the pooled D9901 and D9902 studies (reproduced from Higano et al. 2009^24^; permission pending)

Figure B1 displays sipuleucel-T treatment hazard ratios according to subgroups from the pooled D9901 and D9902 studies. Many of the of the subgroup pairings show that the hazard ratio estimate is different depending on the subgroup comparison. For example, the most extreme difference depicted in the pooled analysis in Appendix Figure B1 is the analysis categorizing bone metastases. The group with 10 or fewer metastases shows a hazard ratio of greater than 2, indicating a strong effect of sipuleucel-T, whereas the group with more than 10 metastases shows a much weaker effect, probably close to 1.3 by visual estimation.

Appendix Figure B2 Sipuleucel-T treatment hazard ratios according to subgroups from the IMPACT trial (reproduced from FDA Clinical Review17)

Figure B2 displays sipuleucel-T treatment hazard ratios according to subgroups from the IMPACT trial. Broad confidence intervals surround most of the subgroup hazard ratios. The only exception to this is the analysis dividing the subjects of the IMPACT trial in age groups divided at 65 years of age. In the subgroup of subjects who were younger than 65 years, the hazard ratio was 1.411 (95% CI: 0.869–2.290), in the direction of harm of sipuleucel-T. The value of the hazard ratio for those 65 or older was not reported in any of the documents, but graphically its value was greater (closer to zero) than the overall hazard ratio for sipuleucel-T treatment effect, is it would have to be to counterbalance the 1.411 hazard ratio for the younger than 65 group. The confidence intervals of the two hazard ratios do not overlap, indicating a highly statistically significant interaction if using statistical tests uncorrected for multiple statistical testing.