# Appendix Tables

Appendix Table A1 Inclusion/Exclusion Criteria and Baseline Characteristics of RCTs of Sipuleucel-T in Castrate-Resistant Prostate Cancer

Study (ref) | Inclusion/exclusion criteria | Baseline characteristic | Sipuleucel-T | Placebo | Comment
IMPACT (11) | Inclusion: metastatic CRPC, asymptomatic or minimally symptomatic, PSA >5, testosterone<50, progressive disease by PSA or imaging, expected survival of ≥6 months Exclusion: ECOG performance ≥2, visceral metastases, pathologic fractures, spinal cord compression, recent treatment (28 days) with steroids, radiation, surgery, systemic therapy, or change in bisphosphonate therapy, past history of >2 chemotherapy regimens, chemotherapy within the past 3 months | Median age | 72 | 70 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | % white | 89.4 | 91.2 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | %Gleason score ≤7 | 75.4 | 75.4 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | % ECOG score 0 | 82.1 | 81.3 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Metastasis bone only | 50.7 | 43.3 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Metastasis soft tissue | 7.0 | 8.2 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Metastasis both | 41.9 | 48.5 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Median PSA | 51.7 | 47.2 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Median PAP | 2.7 | 3.2 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Median LDH | 194 | 193 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | Median alk phos | 99 | 109 | Original protocol required asymptomatic CRPC, Gleason score≤7
IMPACT (11) | | % prior chemotherapy | 19.6 | 15.2 | Original protocol required asymptomatic CRPC, Gleason score≤7
D9901 (29) | Mostly similar to IMPACT, some differences Different inclusion: only asymptomatic CRPC, 25% staining of tumor for PAP Different exclusion: slight differences in prior therapies allowed and time since prior therapies | Median age | 73 | 71
D9901 (29) | | % white | 89 | 93.3
D9901 (29) | | %Gleason score ≤7 | 61 | 55.6
D9901 (29) | | % ECOG score 0 | 75.6 | 82.2
D9901 (29) | | Metastasis bone only | 42.7 | 26.7
D9901 (29) | | Metastasis soft tissue | 6.1 | 8.9
D9901 (29) | | Metastasis both | 51.2 | 64.4
D9901 (29) | | Median PSA | 46 | 47.9
D9901 (29) | | Median PAP | 7 | 6.5
D9901 (29) | | Median LDH | 173.5 | 172
D9901 (29) | | Median alk phos | 102 | 92
D9901 (29) | | % prior chemotherapy | 3.7 | 8.9
D9902A (10) | Identical to D9901 | Median age | 70 | 71
D9902A (10) | Identical to D9901 | % white | 90.8 | 93.9
D9902A (10) | Identical to D9901 | % Gleason score ≤7 | 68.7 | 51.5
D9902A (10) | Identical to D9901 | % ECOG score 0 | 78.5 | 69.7
D9902A (10) | Identical to D9901 | Metastasis bone only | 47.7 | 30.3
D9902A (10) | Identical to D9901 | Metastasis soft tissue | 10.8 | 21.2
D9902A (10) | Identical to D9901 | Metastasis both | 41.5 | 48.5
D9902A (10) | Identical to D9901 | Median PSA | 61.3 | 44.0
D9902A (10) | Identical to D9901 | Median PAP | 4.5 | 5.1
D9902A (10) | Identical to D9901 | Median LDH | 187 | 179
D9902A (10) | Identical to D9901 | Median alk phos | 140 | 105
D9902A (10) | Identical to D9901 | % prior chemotherapy | 11.1 | 9.1

Abbreviations: alk phos: alkaline phosphatase; CRPC: castrate-resistant prostate cancer; ECOG: Eastern Cooperative Oncology Group; LDH: lactate dehydrogenase; PAP: prostatic acid phosphatase; PSA: prostate-specific antigen;

Appendix Table A2 Quality Assessment of RCTs of Sipuleucel-T

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable, Clearly Defined | Appropriate Analysis of Results | Funding or Sponsorship Source Acknowledged | Overall Rating
IMPACT | Y Randomization method specified, stratified by Gleason, bone metastases, bisphosphonate use | U Low loss to follow-up Design caused delay in chemotherapy in control groups | Y Disease progression blinded end point Objective survival end point | U Treatment clearly defined, potential confounding effects of placebo leukapheresis, frozen sipuleucel-T salvage treatment, unblinding after progression, and unbalanced post-progression treatment | Y Prespecified survival analysis Sensitivity analysis for confounding effects | Y | FAIR
D9901 | Y Randomization method specified, stratified by center, bisphosphonate use | U Low loss to follow-up Design caused delay in chemotherapy in control groups | Y Disease progression blinded end point Objective survival end point | U Treatment clearly defined, potential confounding effects of placebo leukapheresis, frozen sipuleucel-T salvage treatment, unblinding after progression, and unbalanced post-progression treatment | U Survival analysis not prespecified Disease progression end point specified | Y | FAIR
D9902A | Y Randomization method specified, stratified by center, bisphosphonate use | U Low loss to follow-up Design caused delay in chemotherapy in control groups | Y Disease progression blinded end point Objective survival end point | U Treatment clearly defined, potential confounding effects of placebo leukapheresis, frozen sipuleucel-T salvage treatment, unblinding after progression, and unbalanced post-progression treatment | U Survival analysis not prespecified Disease progression end point specified | Y | FAIR

Abbreviations: U: unclear; Y: Yes

Appendix Table A3 Description of Issues Regarding Alternative Analyses of Survival Outcomes in the RCTs of Sipuleucel-T

Type of analysis (ref) | Study | Discussion
Single variable adjusted estimate of sipuleucel-T treatment effect (32, 33) | D9901 | Most analyses adjusting for a single baseline characteristic find a statistically significant hazard ratio for sipuleucel-T treatment effect in FDA statistical review.
| IMPACT | Various analyses adjusting for each of 21 baseline factors described as consistent with sipuleucel-T treatment effect in FDA statistical review.
Multivariable adjusted estimate of sipuleucel-T treatment effect (32, 33) | D9901 | Hazard ratio adjusted for 5 variables showed treatment hazard ratio of 0.47, p<0.002. FDA statistical review showed this analysis has missing values which result in exclusion of short surviving sipuleucel-T patients and long surviving placebo patients. FDA statistical review shows other models with hazard ratio not significant.
Multivariable adjusted estimate of sipuleucel-T treatment effect (32, 33) | D9902A | Hazard ratio adjusted for 5 variables showed treatment hazard ratio of 0.52, p=0.023. FDA statistical review showed this analysis has missing values which result in exclusion of short surviving sipuleucel-T patients and long surviving placebo patients.
| IMPACT | Overall survival adjusting for additional baseline prognostic factors described as consistent with primary analysis in FDA statistical review.
Prostate cancer-specific survival (10, 11) | IMPACT | Hazard ratio for treatment effect of 0.77, p=0.02. Most deaths in the study attributed to prostate cancer. Most cause-of-death algorithms likely to attribute death to prostate cancer.
Prostate cancer-specific survival (10, 11) | D9901 | Hazard ratio for treatment effect of 0.49, p<0.002. Most deaths in study (77/94) attributed to prostate cancer. Most cause-of-death algorithms likely to attribute death to prostate cancer.
Prostate cancer-specific survival (10, 11) | D9902A | Hazard ratio for treatment effect of 0.74, p=0.287. Most cause-of-death algorithms likely to attribute death to prostate cancer.

Appendix Table A4 Overall Grade of Strength of Comparative Study Evidence for FDA-labeled Indication for Sipuleucel-T

Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
3 randomized clinical trials. The design provides the strongest evidence for treatment efficacy | The trial design resulted may have resulted in a systematic difference in the subsequent initiation of chemotherapy. Chemotherapy was less frequent and later in the control groups due to use of frozen salvage product. Statistical adjustment methods used do not account for time-dependent confounding. It cannot be assumed that frozen salvage product produces a conservative bias, because it is not the same as sipuleucel-T | The survival findings of the studies are consistent in direction and magnitude. Disease progression outcomes showed no difference. | The outcome of overall survival is the most direct and least subject to bias. | According to a narrow definition of precision based strictly on the magnitude and confidence interval of the treatment effect, along with the consistent direction of 3 studies, the results are precise. | The strength of the body of evidence for this indication is moderate. Concerns regarding bias are the principal reason for this conclusion.

Appendix Table A5 Description of Characteristics of Studies for Off-Label Indications for Sipuleucel-T

Author/Indication (ref) | Patients included | Treatment Protocol | Clinical Outcomes | Other Outcomes
Small et al., 2000 Phase I group (12) Unspecified metastatic CRPC | Median age 67.5 Median PSA 209 ECOG range 0–1 | Escalating dose at 0, 4, 8 weeks, and 24 weeks to stable or improving pts | Time to disease progression | T-cell responses PAP antibodies 50% decrease in serum PSA
Burch et al., 2000 (13) Unspecified metastatic CRPC | Median age 67.5 Median PSA 323 ECOG range 0–1 | Standard dose at 0, 4 weeks. Injection of PA2024 at 8, 12, 16 weeks (3 dose levels of PA2024) | Time to disease progression | T-cell proliferation PAP antibodies GM-CSF antibodies
Burch et al., 2004 (14) Unspecified metastatic CRPC | Median age 72 Median PSA 221 % Gleason ≤7: 58 | Standard dose at 0, 2 weeks. Injection of PA2024 at 4, 8, 12 weeks | Time to disease progression | Decrease in PSA Cellular response to PA2024
Small et al., 2000 Phase II group (12) Nonmetastatic CRPC | Median age 72 Median PSA 14.5 ECOG range 0–1 | Standard dose at 0, 4, 8 weeks, and 24 weeks to stable or improving pts | Time to disease progression | T-cell responses PAP antibodies 50% decrease in serum PSA
Beinart et al., 2005 (34) Nonmetastatic hormone-sensitive recurrent PC | Median age 67 Median PSA 1.6 % Gleason ≤7: 84 | Standard dose at 0, 2, 4 weeks | | 50% decrease in serum PSA Time to PSA progression PSA doubling time
Rini et al., 2006 (35) Nonmetastatic hormone-sensitive recurrent PC | Median age 70 Median PSA 2.3 % Gleason ≤7: 82 | Standard dose at 0, 2, 4 weeks. Bevacizumab every 2 weeks until toxicity or progression | | 50% decrease in serum PSA Time to PSA progression PSA doubling time
PROTECT trial unpublished (23, 36) Nonmetastatic hormone sensitive recurrent PC | Primary therapy was radical prostatectomy No other data available | 3 months of hormonal therapy, then randomized to standard dose or placebo infusion at 0, 2, 4 weeks. Booster dose of drug or placebo at biochemical failure. | Biochemical failure PSA ≥3 Time to distant failure Overall survival | PSA doubling time

Abbreviations: CRPC: castrate-resistant prostate cancer; ECOG: Eastern Cooperative Oncology Group; GM-CSF: granulocyte-macrophage colony-stimulating factor; PAP: prostatic acid phosphatase; PC: prostate cancer; PSA: prostate-specific antigen;

Appendix Table A6 Summary of Other Types of Analysis of Adverse Events in FDA Clinical Review

Description of type of adverse event or analysis | Summary of results and comment
Cause of death | No substantial difference in cause of death between sipuleucel-T-treated groups and placebo
Dropouts and/or Discontinuations | Very few patients dropped out due to treatment-related adverse events
Non-neurologic vascular events | No increased rate of arterial or venous vascular events in sipuleucel-T treated groups
New Primary Cancers | No difference between groups
Respiratory Reactions | Higher rate within one day in sipuleucel-T treated groups consistent with infusion reaction
Autoimmune disorders | No difference in rates of adverse events using subset of terms consistent with autoimmune disorders
Skin disorders | Higher rate of minor disorders in sipuleucel-T treated groups consistent with infusion reaction
Renal insufficiency | No notable differences between groups