# Executive Summary

[underlined: Background.] Sipuleucel-T (Provenge®, Dendreon Corporation) is a recently approved treatment for asymptomatic or minimally symptomatic metastatic castrate-resistant prostate cancer. This technology assessment is a systematic review of studies of the clinical outcomes of sipuleucel-T treatment. The review is organized by three Key Questions. These questions address the following: 1) the outcomes of sipuleucel-T for patients meeting the U.S. Food and Drug Administration (FDA)-labeled indications; 2) the outcomes of sipuleucel-T for patients not meeting the FDA-labeled indication (“off-label use”); and 3) adverse effects of sipuleucel-T treatment. Key Questions 1 and 2 also include subquestions to address possible interactions and mediators of the outcomes of sipuleucel-T treatment.

[underlined: Methods.] This assessment is based on an electronic search of the literature as follows:

- MEDLINE® (inception [1948] through July 13, 2010)
- EMBASE® (inception [1974] through July 13, 2010)
- Cochrane Controlled Trials Register (no date restriction)

In addition, publicly available documents available from the FDA website and some other sources such as clinicaltrials.gov and conference abstract websites were examined for relevant studies. Studies were selected to address the three Key Questions identified for this technology assessment. We abstracted data from full-length randomized, controlled trials (RCTs) and case series studies that utilized sipuleucel-T treatment for patients with prostate cancer and reported at least one clinically relevant outcome of interest.

The quality of included comparative studies was assessed using the general approach to grading evidence developed by the U.S. Preventive Services Task Force (USPSTF). The strength of the overall body of evidence was assessed using a framework developed by AHRQ for the EPC Methods Guide, based on a system developed by the GRADE Working Group.

[underlined: Results.] The electronic literature search yielded 47 records. Among those, 33 were excluded at initial title and abstract review and 14 were retrieved for full-text examination. Including documents retrieved from other sources, data were available from 10 nonoverlapping data sets. Data from three studies describing results of comparative studies were abstracted for studies examining the FDA-labeled indication. Data from seven studies describing results of any study design were abstracted for studies examining off-label indications. Data from a single analysis of pooled data from four comparative studies were abstracted for the analysis of adverse effects of sipuleucel-T.

## Key Question 1 What is the evidence regarding the clinical outcomes of sipuleucel-T for its FDA-approved indication; asymptomatic or minimally symptomatic metastatic androgen-independent prostate cancer?

Three randomized clinical trials of sipuleucel-T share a common study design which includes control groups that underwent leukapheresis and infusion of untreated cells, availability of a salvage product for the control group upon disease progression, and treatment as needed in either group upon disease progression. Two of the three studies were statistically significant for survival in favor of sipuleucel-T in unadjusted or prespecified analyses; the third study showed a similar magnitude of effect but was not statistically significant. None of the studies showed a statistically significant difference in disease progression end points. Quality of life outcomes were not assessed. Post-disease progression chemotherapy was a common event for participants in these clinical trials. Analyses undertaken to account for potential confounding effects of these subsequent treatments and other factors produced similar estimates of treatment effect, but such methods may be limited in the ability to fully account for such effects. The strength of the body of evidence for improved outcomes was graded as moderate.

## Question 1a What is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

Regarding patient baseline characteristics, there are no conclusive findings regarding potential interactions with sipuleucel-T treatment. One study showed a significant interaction with age at a cutoff of 65 years, but analysis of pooled data showed less extreme results and makes this finding inconclusive. The conclusions to be drawn regarding the association product parameters and survival are limited because it is not possible to separate a treatment effect from an inherent characteristic of the patient. Associations were found with several product parameter measures, but no such analyses are available from such measures done on the control groups of the studies. Post-progression chemotherapy was a common event in these studies, but the existing analysis is insufficient to determine the independence or interaction of sipuleucel-T with such treatment.

## Key Question 2 What is the level of evidence and summary of evidence for off-label indications for sipuleucel-T?

Outcomes for sipuleucel-T have been reported for patients with metastatic castrate-resistant prostate cancer without specification of symptoms, nonmetastatic castrate-resistant prostate cancer, and nonmetastatic hormone-sensitive prostate cancer. Six sets of findings for off-label indications are all case series studies. The case series studies all differed in the treatment protocol for sipuleucel-T than the protocol currently used. Without a comparison group, it is not possible to determine whether the outcomes observed are attributable to sipuleucel-T. One randomized clinical trial is unpublished, with a conference abstract reporting no significant difference for the principal outcome of biochemical failure. There is insufficient evidence to evaluate the outcomes for off-label indications.

## Question 2a For off-label indications, what is the evidence regarding the relationship between baseline patient characteristics, measurable characteristics of treatment such as cell number or immune response characteristics of patients, post-treatment factors, and sipuleucel-T on outcomes of treatment?

In light of the insufficient evidence for Key Question 2, there is insufficient evidence to evaluate this additional question.

## Key Question 3 What is the evidence regarding adverse events potentially attributable to the use of sipuleucel-T?

A pooled analysis of the three randomized trials for the FDA-labeled indication and one randomized trial for an off-label indication was reviewed. Sipuleucel-T causes events consistent with an infusion reaction, which are rarely severe enough to cause hospitalization. Sipuleucel-T therapy also is associated with catheter-related infections. For other types of adverse effects, the data are inconclusive. FDA is requiring a postmarketing registry to assess the incidence of cerebrovascular events. The data are inconclusive regarding the association of cerebrovascular events and sipuleucel-T treatment. No associations of product parameters or patient characteristics with adverse events were identified.

[underlined: Conclusions/Future Research Issues]. Three randomized clinical trials of sipuleucel-T are consistent with longer overall survival in patients meeting the FDA-labeled indication. This conclusion is tempered by consideration of a trial design with potential for confounding due to a systematic difference in application of effective post-progression treatment, likely to be due to delays caused administration of frozen salvage product. The quantity of benefit of sipuleucel-T is less certain because of these issues. There is little evidence regarding potential interactions with baseline patient characteristics but the current studies are weakly powered to detect such interactions. There is insufficient evidence for any off-label indication.

Future clinical trials of sipuleucel-T should be robustly designed for a survival end point. Although it is not possible to dictate all possible treatments being employed in clinical trials, particularly as patients’ disease progresses, study designs should avoid the potential for systematic biases in the use of post-progression treatments and ensure an equal standard of care for patients in all treatment arms. Because the effect of sipuleucel-T is not apparent early in the course of disease after treatment and in the context of a substantial amount of eventual chemotherapeutic treatment, it would be important to understand the existence of and nature of interactions between sipuleucel-T and subsequent treatments. Such information is critical for decisions physicians and patients need to make as they plan how to treat the patient’s cancer.