# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Dan L. Longo, M.D.
  Deputy Editor
  New England Journal of Medicine
  Boston, Massachusetts
- Elizabeth Plimack, M.D., M.S.
  Assistant Professor
  Fox Chase Cancer Center
  Philadelphia, Pennsylvania
- Sandhya Srinivas, M.D.
  Associate Professor of Medicine (Oncology)
  Stanford University Medical Center
  Stanford, CA