# References

1 American Cancer Society. What are the key statistics about prostate cancer?. 2010. Available online at: www.cancer.org/Cancer/ProstateCancer/DetailedGuide/prostate-cancer-key-statistics. Last accessed October 2010.
2 Mohler J, Bahnson RR, Boston B, et al. NCCN clinical practice guidelines in oncology: prostate cancer. J Natl Compr Canc Netw. 2010;8(2):162-200. [pmid: 20141676]. Version 2.2010, Available online at: www.nccn.org. Last accessed October 2010.
3 Halabi S, Small EJ, Kantoff PW, et al. Prognostic model for predicting survival in men with hormone-refractory metastatic prostate cancer. J Clin Oncol. 2003;21(7):1232-1237. [pmid: 12663709].
4 Smaletz O, Scher HI, Small EJ, et al. Nomogram for overall survival of patients with progressive metastatic prostate cancer after castration. J Clin Oncol. 2002;20(19):3972-3982. [pmid: 12351594].
5 Armstrong AJ, Garrett-Mayer ES, Yang YC, et al. A contemporary prognostic nomogram for men with hormone-refractory metastatic prostate cancer: a TAX327 study analysis. Clin Cancer Res. 2007;13(21):6396-6403. [pmid: 17975152].
6 Tannock IF, de Wit R, Berry WR, et al. Docetaxel plus prednisone or mitoxantrone plus prednisone for advanced prostate cancer. N Engl J Med. 2004;351(15):1502-1512. [pmid: 15470213].
7 Berthold DR, Pond GR, Soban F, et al. Docetaxel plus prednisone or mitoxantrone plus prednisone for advanced prostate cancer: updated survival in the TAX 327 study. J Clin Oncol. 2008;26(2):242-245. [pmid: 18182665].
8 Petrylak DP, Tangen CM, Hussain MH, et al. Docetaxel and estramustine compared with mitoxantrone and prednisone for advanced refractory prostate cancer. N Engl J Med. 2004;351(15):1513-1520. [pmid: 15470214].
9 Armstrong AJ, George DJ. Optimizing the use of docetaxel in men with castration-resistant metastatic prostate cancer. Prostate Cancer Prostatic Dis. 2010;13(2):108-116. [pmid: 20066005].
10 Dendreon Corporation. Cellular, tissue and gene therapies advisory committee briefing document. 2007. Available online at: www.fda.gov/ohrms/dockets/ac/07/briefing/2007-4291B1_01.pdf. Last accessed October 2010.
11 Kantoff PW, Higano CS, Shore ND, et al. Sipuleucel-T immunotherapy for castration-resistant prostate cancer. N Engl J Med. 2010;363(5):411-422. [pmid: 20818862].
12 Small EJ, Fratesi P, Reese DM, et al. Immunotherapy of hormone-refractory prostate cancer with antigen-loaded dendritic cells. J Clin Oncol. 2000;18(23):3894-3903. [pmid: 11099318].
13 Burch PA, Breen JK, Buckner JC, et al. Priming tissue-specific cellular immunity in a phase I trial of autologous dendritic cells for prostate cancer. Clin Cancer Res. 2000;6(6):2175-2182. [pmid: 10873066].
14 Burch PA, Croghan GA, Gastineau DA, et al. Immunotherapy (APC8015, Provenge) targeting prostatic acid phosphatase can induce durable remission of metastatic androgen-independent prostate cancer: a Phase 2 trial. Prostate. 2004;60(3):197-204. [pmid: 15176049].
15 U.S. Food and Drug Administration. Full Prescribing Information: Provenge. 2010. Available online at: www.fda.gov/downloads/BiologicsBloodVaccines/CellularGeneTherapyProducts/ApprovedProducts/UCM213957.pdf. Last accessed October 2010.
16 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2 [updated September 2009]. The Cochrane Collaboration. 2009. Available online at www.cochrane-handbook.org. Last accessed October 2010.
17 U.S. Food and Drug Administration. Clinical review for BLA 125197. 2010. Available online at: www.fda.gov/downloads/BiologicsBloodVaccines/CellularGeneTherapyProducts/ApprovedProducts/UCM214540.pdf. Last accessed October 2010.
18 Harris RP, Helfand M, Woolf SH, et al. for the Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
19 Santaguida PL, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. 2005. Available online at: http://hiru.mcmaster.ca/epc/mcharm.pdf. Last accessed October 2010.
20 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Available online at: effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Last accessed October 2010.
21 Lohr KN, Helfand M, Owens DK, et al. Grading the strength of a body of evidence. J Clin Epidemiol. 2010;63(5):513-523. [pmid: 19595577].
22 Guyatt GH, Oxman AD, Vist GE, et al. for the GRADE Working Group. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-926. [pmid: 18436948].
23 Beer TM, Bernstein T, Corman HM, et al. Randomized trial of active cellular immunotherapy with sipuleucel-T in androgen dependent prostate cancer (ADPC). Abstract. J Clin Oncol. 2007;25(18s):5059.
24 Higano CS, Schellhammer PF, Small EJ, et al. Integrated data from 2 randomized, double-blind, placebo-controlled, phase 3 trials of active cellular immunotherapy with sipuleucel-T in advanced prostate cancer. Cancer. 2009;115(16):3670-3679. [pmid: 19536890].
25 Petrylak DP, Dawson NA, Gardner T, et al. Persistence of immunotherapy survival effects of sipuleucel-T and relationship to postrandomization docetaxel use in phase II studies. Abstract. J Clin Oncol. 2010;28(15s):4551.
26 Higano CS, Small EJ, Schellhammer P, et al. Predictors of outcome and subgroup results from the integrated analysis of sipuleucel-T trials in metastatic castration-resistant prostate cancer. Abstract. J Clin Oncol. 2010;28(15s):4550.
27 Stewart FP, dela Rosa CP, Sheikh NA, et al. Correlation between product parameters and overall survival in three trials of sipuleucel-T, an autologous active cellular immunotherapy for the treatment of prostate cancer. J Clin Oncol. 2010;28(15s):4552.
28 Kantoff P, Higano CS, Berger ER, et al. Updated survival results of the IMPACT trial of sipuleucel-T for metastatic castration-resistant prostate cancer (CRPC). 2010. Available online at: www.asco.org/ASCOv2/Meetings/Abstracts?&vmview=abst_detail_view&confID=73&abstractID=30778. Last accessed October 2010.
29 Small EJ, Schellhammer PF, Higano CS, et al. Placebo-controlled phase III trial of immunologic therapy with sipuleucel-T (APC8015) in patients with metastatic, asymptomatic hormone refractory prostate cancer. J Clin Oncol. 2006;24(19):3089-3094. [pmid: 16809734].
30 U.S. Food and Drug Administration. Biologics license application (BLA) medical review. 2007. Available online at: www.fda.gov/downloads/BiologicsBloodVaccines/CellularGeneTherapyProducts/ApprovedProducts/UCM214560.pdf. Last accessed October 2010.
31 U.S. Food and Drug Administration. Clinical briefing document, Cellular, Tissue and Gene Therapies Advisory Committee Meeting, March 29, 2007 for BLA #125197. 2007. Available online at: www.fda.gov/ohrms/dockets/ac/07/briefing/2007-4291B1_2a.pdf. Last accessed October 2010.
32 U.S. Food and Drug Administration. Statistical review and evaluation for BLA 125197/0. 2007. Available online at: www.fda.gov/downloads/BiologicsBloodVaccines/CellularGeneTherapyProducts/ApprovedProducts/UCM214567.pdf. Last accessed October 2010.
33 U.S. Food and Drug Administration. Statistical review and evaluation for BLA 125197/0. 2010. Available online at: www.fda.gov/downloads/BiologicsBloodVaccines/CellularGeneTherapyProducts/ApprovedProducts/UCM214543.pdf. Last Accessed October 2010.
34 Beinart G, Rini BI, Weinberg V, et al. Antigen-presenting cells 8015 (Provenge) in patients with androgen-dependent, biochemically relapsed prostate cancer. Clin Prostate Cancer. 2005;4(1):55-60. [pmid: 15992463].
35 Rini BI, Weinberg V, Fong L, et al. Combination immunotherapy with prostatic acid phosphatase pulsed antigen-presenting cells (provenge) plus bevacizumab in patients with serologic progression of prostate cancer after definitive local therapy. Cancer. 2006;107(1):67-74. [pmid: 16736512].
36 U.S. National Institutes of Health. Provenge (TM) for the Treatment of Hormone Sensitive Prostate Cancer (PROTECT). Available online at: http://clinicaltrials.gov/ct2/show/NCT00779402?term=provenge&rank=1. Last accessed October 2010.
37 Dendreon Corporation. A randomized, double blind, placebo-controlled phase 3 trial of immunotherapy with autologous antigen presenting cells loaded with PA2024 (Provenge, Sipuleucel-T, APC8015) in men with metastatic androgen independent prostatic carcinoma. 2008. Available online at: www.nejm.org/doi/suppl/10.1056/NEJMoa1001294/suppl_file/nejmoa1001294_protocol.pdf. Last accessed October 2010.
38 Hernan MA, Brumback B, Robins JM. Marginal structural models to estimate the joint causal effect of nonrandomized treatments. J Am Stat Assoc. 2001;96:440-448.