# RESULTS

## Overview

Literature searches identified 1897 unique citations. By applying the eligibility and exclusion criteria to titles and abstracts of all identified citations, we obtained full-text copies of 510 citations. After re-applying the criteria for inclusion, we ultimately included 26 publications. See Appendix E for a list of excluded studies and reasons for exclusion at this stage. We excluded studies that used a 5-HT3 antagonist alone,13–18 in combination with another, non-corticosteroid drug (e.g., metoclopramide, lorazepam, etc.),19, 20 and in which the dosage form or route of the corticosteroid was variable, unclear, or both.18, 21–26 Figure 1 shows the flow of study selection.

Figure 1 Results of literature search

## Key Question 1 What are the comparative overall benefits of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation? Outcomes of interest include (at least): ability to control nausea and vomiting; ability to tolerate sequential chemotherapy sessions; quality of life measures

### A How do all-oral regimens compare to each other?

#### Comparison of regimens with and without aprepitant

We included three fair-quality randomized controlled trials (RCTs) that compared an all-oral, three-drug regimen of aprepitant, ondansetron, and dexamethasone to an all-oral, two-drug regimen of ondansetron plus dexamethasone.13–15 Two of the trials were conducted in a total of 946 patients with breast cancer undergoing moderately emetogenic chemotherapy based on an anthracycline (i.e., doxorubicin, epirubicin) and cyclophosphamide.13, 14 The first of these was a multi-center, international trial in primarily white females with a mean age of 53 years.13

The second trial14 evaluated 124 women of ethnic Chinese origin who were enrolled from a single-center in Hong Kong (mean age of 47.5 years), 44 of which had taken part in the earlier multi-center trial.13 The third trial was conducted in a broader population of 848 patients (77% female, mean age of 56 years) with various malignancies (51% breast cancer, 20% colon cancer, 12% lung cancer, 4% ovarian cancer) and undergoing moderately emetogenic chemotherapy based on either an anthracycline and cyclophosphamide (48%) or a non-anthracycline and cyclophosphamide regimen (52%).15

In all three RCTs, treatment was administered according to the treatment regimens listed in Table 3.

Table 3 Oral antiemetic regimens in randomized controlled trials of 5-HT3 antagonist plus a corticosteroid, used with or without aprepitant

Regimen type | Drugs (oral) | Day 1 | Day 2 | Day 3
Three-drug regimen | Aprepitant | 125 mg, 1 hour before chemotherapy | 80 mg qd | 80 mg qd
Three-drug regimen | Ondansetron | 8 mg, 30 to 60 minutes before chemotherapy 8 mg, 8 hours after first dose | None | None
Three-drug regimen | Dexamethasone | 12 mg, 30 minutes before chemotherapy | None | None
Two-drug regimen | Ondansetron | 8 mg, 30 to 60 minutes before chemotherapy 8 mg, 8 hours after first dose | 8 mg bid | 8 mg bid
Two-drug regimen | Dexamethasone | 20 mg, 30 minutes before chemotherapy | None | None

Abbreviations: bid, twice daily; qd, once daily.

Compared to an all-oral, two-drug regimen of ondansetron and dexamethasone, there was moderate-strength evidence that an all-oral, three-drug regimen with aprepitant, ondansetron, and dexamethasone did not significantly increase the proportion of women of ethnic Chinese origin undergoing moderately emetogenic chemotherapy that reported total control during the overall trial period (26% compared with 31%; RR, 0.84; 95% CI, 0.48 to 1.47), or during the acute (54% compared to 56%; RR, 0.94; 95% CI, 0.68 to 1.30) or delayed periods (56% compared with 58%; RR, 0.82; 95% CI, 0.57 to 1.17).14 However, this same trial also provided low-strength evidence of a significantly lower rate of delay in subsequent cycle of chemotherapy for the aprepitant group (8% compared with 27%; RR, 0.29; 95% CI, 0.12 to 0.71), likely due in part to the significantly higher rate of neutropenia in the two-drug regimen group (53% compared with 35%; P=0.0468).14 The outcomes of total control and delay in subsequent chemotherapy sessions were not reported in the other two trials.13, 15

For complete response, although this outcome was reported in all three trials, our pooled analysis did not include data from the trial of Chinese women14 due to the overlap of 44 patients also included in the trial by Warr et al (2009).13

Compared to an all-oral, two-drug regimen without aprepitant, there was high-strength evidence from two trials that an all-oral, three-drug regimen with aprepitant significantly increased the proportion of patients reporting a complete response 0 to 120 hours (overall phase) following initiation of chemotherapy (pooled rates, 60% compared with 49%; RR, 1.22; 95% CI, 1.12 to 1.33).13, 15 The difference between groups in the smaller trial of Chinese women was not significant (47% compared with 42%; P=0.58).14 Pooled rates of complete response were also significantly greater with the all-oral, three-drug regimen with aprepitant during the acute (82% compared with 74%; RR, 1.11; 95% CI, 1.06 to 1.16) and delayed periods (63% compared with 55%; RR, 1.15; 95% CI, 1.06 to 1.24) in the larger trials, but not in the smaller trial of Chinese women (acute: 72.1% compared with 72.6%; P=0.95; delayed: 64% compared with 58%; P=0.51).14

Quality-of-life assessment was conducted in two of three trials using the Functional Living Index-Emesis (FLIE) questionnaire.13, 14 The FLIE questionnaire contains nine items in each of two domains, nausea and vomiting, and involves rating each item on a 100-mm visual analog scale with higher scores indicating a worse quality of life. In the first trial, a significantly greater proportion of patients in the aprepitant group reported minimal or no impact on daily living of the combined domains (63% compared with 56%; P=0.019).13 However, in the second trial, there was no significant difference between the all-oral, three-drug regimen with aprepitant and the all-oral, two-drug regimen without aprepitant when the mean total scores were compared (11.24 compared with 23.12; P=0.45).14 Again, sample size may have been inadequate to find a statistically significant difference.

#### Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid, without aprepitant

We included one fair-quality RCT that compared two all-oral regimens of a 5-HT3 antagonist plus a corticosteroid.16 A total of 65 chemotherapy-naïve patients were randomized to receive either a single dose of oral granisetron 1 mg or oral ondansetron 16 mg, both in combination with oral dexamethasone 12 mg, and administered within 30 minutes of moderately emetogenic chemotherapy. The study sample was comprised of mostly women (75%) with breast cancer (62%). The median age was 62.5 years in the granisetron group (range 25 to 84) and 59 years in the ondansetron group (range 20 to 91). This trial only evaluated outcomes over 24 hours after starting chemotherapy and did not report complete response, quality of life, or ability to tolerate sequential chemotherapy sessions. There was no significant difference between the granisetron and ondansetron groups in the proportion of patients who experienced total control of nausea and emesis over 24 hours after starting chemotherapy (46% compared with 45%; P=0.94). Overall, this trial provided a low strength of evidence that there was no significant difference between all-oral regimens for the outcome of 24-hour total control (RR, 1.02; 95% CI, 0.58 to 1.76) (Appendix F).

### B How do all-oral regimens compare to all-injectable regimens?

We did not find any trials that compared an all-oral regimen to an all-injectable regimen, with or without aprepitant.

### C How do mixed oral and injectable regimens compare?

#### Comparison of mixed oral and injectable regimens with and without aprepitant

We included eight RCTs that compared mixed oral and injectable regimens with and without aprepitant (Evidence Table 1).17–24 All RCTs were rated fair quality due to insufficient detail provided for verification of adequate allocation concealment methods (Evidence Table 2).

Two trials evaluated regimens including aprepitant in an older formulation and dose that is now unavailable in the United States (400 mg on day 1 and 300 mg on days 2 through 5).21, 24 Because of the difference in aprepitant formulation and dose, these trials were not included in any meta-analyses. In the remaining six trials,17–20, 22, 23 on the first day of treatment, the three-drug regimen was comprised of oral aprepitant 125 mg, an intravenous 5-HT3 antagonist (ondansetron 32 mg or palonosetron 0.25 mg), and oral dexamethasone 12 to 20 mg, and the two-drug regimen was comprised of the same dosage of the intravenous 5-HT3 antagonist and the same or a slightly higher19, 22, 23 dosage of oral dexamethasone. On subsequent days, the aprepitant-based and control group regimens varied and are listed in Table 4. Two trials included a third treatment arm in which aprepitant was administered only on day 1 and was compared to the multi-day aprepitant regimen.19, 21 Results of those comparisons will be discussed under Key Question 3d below. Another two trials included a third treatment arm in which aprepitant was administered at 375 mg on day 1 and 250 mg on subsequent days.17, 18 However, during the conduct of these trials, new data became available suggesting a pharmacokinetic interaction between the higher dosages of aprepitant and dexamethasone, in which the dexamethasone levels were increased by approximately two-fold. Therefore, those treatment arms were discontinued in both trials and results will not be discussed here.

Table 4 Treatment regimens on days two to five

Author Year | Aprepitant group | Control group
Hesketh 2003,^20^ Poli-Bigelli 2003,^22^ Herrington 2008,^19^ | Aprepitant 80 mg qd on days 2–3 Dexamethasone 8 mg bid on days 2–4 | Dexamethasone 8 mg bid on days 2–4
de Wit 2003,^18^ Chawla 2003^17^ | Aprepitant 80 mg qd on days 2–5 Dexamethasone 8 mg qd on days 2–5 | Dexamethasone 8 mg qd on days 2–5
Schmoll 2006^23^ | Aprepitant 80 mg qd on days 2–3 Dexamethasone 80 mg qd on days 2–4 | Ondansetron 8 mg plus dexamethasone 8 mg, both bid on days 2–4

Abbreviations: bid, twice daily; qd, once daily.

In all trials, patients were undergoing highly emetic chemotherapy. In all but one trial, there were more males than females, with primarily respiratory and urogenital malignancies. In the remaining trial, patients were primarily female with breast cancer.19 Mean ages ranged from 53 years to 64 years.

Three trials provided high-strength evidence that, compared with treatment with a mixed, two-drug regimen of intravenous ondansetron and oral dexamethasone on day 1 followed by monotherapy with oral dexamethasone on days 2 through 4 to 5, a mixed, three-drug regimen with oral aprepitant, intravenous ondansetron, and oral dexamethasone on day 1 followed by oral aprepitant and oral dexamethasone on days 2 through 3 to 5 significantly increases the proportion of patients undergoing highly emetogenic chemotherapy that reported total control (mean rates, 45% compared with 35%; RR, 1.30; 95% CI, 1.10 to 1.54) and complete response (mean rates, 68% compared with 47%, RR, 1.45; 95% CI, 1.32 to 1.60, Figure 2) during the overall study period (Appendix F).20,22,19 The benefit of adding oral aprepitant may be particularly attributed to its continued administration during the delayed period (days 2 through 4 to 5), when therapy in the control group was limited to monotherapy with oral dexamethasone (delayed period total control: mean rates, 50% compared with 38%; RR, 1.36; 95% CI, 1.11 to 1.67; complete response [Figure 3]: mean rates, 72% compared with 50%; RR, 1.43; 95% CI, 1.31 to 1.56). Whereas the magnitude of benefit for a regimen of oral aprepitant on days 2 and 3 plus oral dexamethasone on days 2 through 4 compared with a regimen of oral ondansetron plus oral dexamethasone on days 2 through 4 for complete response was smaller, but still statistically significant in the overall study period (RR, 1.19; 95% CI, 1.05 to 1.35) and delayed period (RR, 1.17; 95% CI, 1.04 to 1.33).23 Also, across all trials, the magnitude of benefit for an aprepitant-based regimen was smaller, but still statistically significant during the acute period for total control (mean rates, 67% compared with 60%; RR, 1.12; 95% CI, 1.03 to 1.21) and for complete response (mean rates, 84% compared with 72%; RR, 1.15; 95% CI, 1.10 to 1.21; Figure 4).

Figure 2 Complete response during overall treatment period of mixed oral and injectable antiemetic regimens with aprepitant compared to without aprepitant

Evaluation of non-combinability of studies

Cochran Q = 1.335762 (df=2) P=0.5128

I^2^ (inconsistency) = 0% (95% CI, 0 to 72.9)

Figure 3 Complete response during delayed treatment period of mixed oral and injectable antiemetic regimens of a 5-HT3 antagonist and a corticosteroid plus aprepitant compared to without aprepitant

Evaluation of non-combinability of studies

Cochran Q = 1.90926 (df=2) P=0.385

I^2^ (inconsistency) = 0% (95% CI, 0 to 72.9)

Figure 4 Complete response during acute treatment period of mixed oral and injectable antiemetic regimens of a 5-HT3 antagonist and a corticosteroid plus aprepitant compared to without aprepitant

Evaluation of non-combinability of studies

Cochran Q = 3.272039 (df=4) P=0.5134

I^2^ (inconsistency) = 0% (95% CI, 0 to 64.1)

Quality-of-life assessment was conducted in two trials, again using the FLIE questionnaire.20, 22 In both trials, greater proportions of patients in the aprepitant groups reported minimal or no impact of chemotherapy-induced nausea and vomiting on quality of life, as measured by the total FLIE score (mean rates, 74% compared with 64%; RR, 1.16; 95% CI, 1.07 to 1.26).

Evidence on the impact of antiemetic regimens on the patient’s ability to tolerate subsequent chemotherapy sessions was limited to a pooled analysis of data from the multiple-cycles extensions of the two pivotal trials submitted to the FDA to obtain approval for aprepitant (study 052 and 054),20, 22 which found that there was no significant difference between mixed oral and injectable regimens, with and without aprepitant, in rate of completion of all six cycles (26% in both groups).25 However, because the reasons for not completing all six cycles were not limited to the impact of antiemetic regimens (e.g., ineligible, withdrawals of consent from study, completed chemotherapy, no response to chemotherapy, other, etc.), this evidence did not represent a direct link between these treatments and the specific outcome of interest.

#### Comparison of mixed oral and injectable regimens of a 5-HT3 antagonist plus a corticosteroid

We included five RCTs that compared mixed oral and injectable two-drug regimens.26–30 Three trials were rated fair quality26–28 and two trials were rated poor quality.29, 30 Among the three fair-quality trials, all involved a comparison of a mixed regimen of an oral 5-HT3 antagonist plus intravenous dexamethasone to an all-injectable regimen of a 5-HT3 antagonist plus dexamethasone.26–28 Further, one trial involved an additional comparison of two different mixed oral and injectable regimens, each comprised of an oral 5-HT3 antagonist plus intravenous dexamethasone.28

Table 5 provides details of the antiemetic regimens and patient characteristics. All three trials had small sample sizes (≤ 102 patients) and were conducted in single centers. The trials were heterogeneous with regard to chemotherapy emetic risk category, primary malignancy, and gender distribution. In two trials patients were receiving highly emetogenic chemotherapy.27, 28 In the third trial, 43% of patients were receiving moderately emetogenic chemotherapy and 57% were receiving highly emetogenic chemotherapy.

Table 5 Antiemetic regimens and patient characteristics

Author Year (Sample size) | Granisetron regimen | Ondansetron regimen | Dexamethasone dosage | Primary malignancy | Female (%)
Fox-Geiman 2001 (N=102) | 1 mg PO, Q12 hrs | 1. 32 mg IV qd; 2. 8 mg PO, Q8 hrs | 10 mg IV | 100% bone marrow transplant | 72%
Chiou 2000 (N=51) | 1 mg PO, Q12 hrs | 8 mg IV, Q8 hrs | 10 mg IV | 35% Non-Hodgkin’s lymphoma | 37%
Chua 2000 (N=94) | 3 mg IV, qd | 8 mg IV before chemo/8 mg PO at 4 and 8 hrs post-chemo | 20 mg IV | 80% nasopharynx | 13%

Abbreviations: IV, intravenous; PO, palonosetron; qd, once daily; Q, every.

Overall, low- to moderate-strength of evidence (Appendix F) indicated that statistically significant differences were not found in complete acute response rates when mixed oral and injectable regimens were compared to all-injectable regimens (RR, 1.00; 95% CI, 0.88 to 1.13)26–28 or when different mixed oral and injectable regimens were compared (RR, 0.97; 95% CI, 0.88 to 1.07).28 In two trials, complete acute response rates ranged from 84% to 95%^26, 28^ and in the third trial were not reported (P=0.262).27

Similarly, these trials provided low- to moderate-strength evidence (Appendix F) indicating that statistically significant differences were not found in complete and delayed complete response rates when mixed oral and injectable regimens were compared to all-injectable regimens (RR, 0.92; 95% CI, 0.59 to 1.45),26, 28 or when different mixed oral and injectable regimens were compared (RR, 1.00; 95% CI, 0.60 to 1.66).28 In patients undergoing highly emetogenic regimens prior to stem cell transplantation, rate of delayed complete response ranged from 47% to 48% for mixed oral and injectable regimens and was 49% for the all-injectable regimen.28 In patients with mixed malignancies in Taiwan, the rates of delayed complete response were relatively lower (16% for the mixed oral and injectable group and 19% for the all-injectable group).26 These trials did not report total control, quality of life, or ability to tolerate sequential chemotherapy sessions.

### D How do regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy compare to those regimens given for longer periods of time?

One RCT compared regimens given immediately prior to and for 48 hours after initiation of chemotherapy to those given for longer periods of time.21 On day 1, all patients received oral aprepitant 400 mg, intravenous granisetron 10 μg/kg, and oral dexamethasone 20 mg. Then, on days 2 through 5, the patients in group 1 also received 300 mg of oral aprepitant whereas the patients in group 2 received placebo. Patients were primarily male undergoing highly emetogenic chemotherapy for lung, gastrointestinal, and head and neck malignancies. Although this trial found no significant difference in complete delayed response between the multi-day aprepitant group (52%) compared with the single-day group (43%; RR, 1.22; 95% CI, 0.82 to 1.84), because this trial evaluated an older formulation and dose of aprepitant that is unavailable in the United States, this evidence was insufficient for drawing conclusions for this question regarding the current FDA-approved product and dosage regimen.21, 24

### E Summary of evidence

The summary of evidence for this Key Question is presented in Table 6, below.

Table 6 Summary of the evidence for Key Question 1

Key Question | Outcome Strength of evidence | Conclusions
1.A. How do oral regimens compare to each other?
Comparison of regimens with and without aprepitant in moderately emetogenic chemotherapy | Total Control Low | No significant advantage for all-oral regimens of aprepitant, a 5-HT3 antagonist and a corticosteroid for moderately emetogenic chemotherapy during overall (RR, 0.84; 95% CI, 0.48 to 1.47), acute (RR, 0.94; 95% CI, 0.68 to 1.30), or delayed periods (RR, 0.82; 95% CI, 0.57 to 1.17)
| Complete Response Moderate-High | High-strength evidence of modest, but significant, advantages for the aprepitant regimen during the overall (RR, 1.22; 95% CI, 1.12 to 1.33) and delayed period (RR, 1.15; 95% CI, 1.06 to 1.24). For the acute period, the strength of evidence for the advantage of the aprepitant regimen was only moderate (RR, 1.11; 95% CI, 1.06 to 1.16) due to the nonsignificant difference in the RCT of Chinese women (72.1% vs. 72.6%).
| Delay in subsequent chemotherapy Moderate | Significantly lower proportion of patients with a delay in subsequent chemotherapy in the aprepitant group (RR, 0.29; 95% CI, 0.12 to 0.71).
| Quality of life Not rated | Negative impact on quality of life was significantly lower in the aprepitant group in one of two RCTs, based on scores on the FLIE questionnaire.
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Total Control: Acute Low | No significant difference between regimens prior to moderately emetogenic chemotherapy (RR, 1.02; 95% CI, 0.58 to 1.76).
1.B. How do oral regimens compare to injectable regimens?
| All Insufficient | No trials included.
1.C. How do mixed oral and injectable regimens compare?
Comparison of regimens with and without aprepitant in highly emetogenic chemotherapy | Total Control High | Mixed oral and injectable regimens with aprepitant are superior to those without during the overall (RR, 1.30; 95% CI, 1.10 to 1.54), acute (RR, 1.12; 95% CI, 1.03 to 1.21), and delayed periods (RR, 1.36; 95% CI, 1.11 to 1.67).
| Complete Response High | Mixed oral and injectable regimens with aprepitant are superior to those without during the overall (RR, 1.45; 95% CI, 1.32 to 1.60), acute (RR, 1.15; 95% CI, 1.10 to 1.21), and delayed periods (RR, 1.43; 95% CI, 1.31 to 1.56).
| Quality of life Not rated | Greater proportions in the aprepitant groups reported “minimal or no impact” of chemotherapy-induced nausea and vomiting on quality of life, based on total FLIE scores (RR, 1.16; 95% CI, 1.07 to 1.26).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Complete Response Low | No significant differences between regimens during the overall (RR, 0.97; 95% CI, 0.88 to 1.07), acute (RR, 0.97; 95% CI, 0.88 to 1.07), or delayed treatment periods (RR, 1.00; 95% CI, 0.60 to 1.66) in patients undergoing moderate to highly emetic chemotherapy.
1.D. How do regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy compare to those regimens given for longer periods of time?
Comparison of regimens with and without aprepitant | Complete Response: Delayed Insufficient | Evidence from 1 RCT of an older, unavailable formulation and dose of aprepitant was insufficient for drawing conclusions about the current FDA-recommended dosage regimen for this question.

Abbreviations: FLIE, Functional Living Index-Emesis questionnaire; FDA, US Food and Drug Administration; RCT, randomized controlled trial.

## Key Question 2 What are the harms of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation?

Data on harms were obtained from the same groups of randomized controlled trials (RCTs) as included for evaluation of benefits. The details of their treatment regimen and patient population characteristics can be found in Key Question 1 (above).

### A How do all-oral regimens compare to each other?

#### Comparison of all-oral regimens with and without aprepitant

Data on harms was provided by three RCTs that compared oral regimens with and without aprepitant in patients undergoing moderately emetogenic chemotherapies.13–15 Incidence of patients with one or more adverse event was only reported in one trial of 848 patients, which provided moderate strength evidence of no significant difference between all-oral regimens with or without aprepitant (63% compared with 67%; RR, 0.93; 95% CI, 0.85 to 1.03).15 Differences in incidences of individual adverse events were not generally significant. The only exception came from the small, single-center trial of ethnic Chinese women in which neutropenia was found to occur statistically significantly more often in the two-drug group compared to the three-drug group (35% compared with 53%; P=0.05).14

#### Comparison of all-oral regimens of a 5-HT3 antagonist plus a corticosteroid

In one fair-quality RCT (N=65) that compared two oral regimens of a 5-HT3 antagonist plus a corticosteroid, there was no statistically significant difference (P values not reported) between a single-dose of oral granisetron 1 mg or oral ondansetron 16 mg, both in combination with oral dexamethasone 12 mg, in the proportion of patients with no adverse events (68% compared with 48%).16 However, because the trial was small, and the absolute difference was 20%, there is a chance that a larger trial would identify a statistically significant difference. Significant differences were also not found with the most common adverse events of headache, dry mouth, diarrhea, and flushing.16 Overall, this trial provided a low strength of evidence (Appendix F) that there is no significant difference between all-oral regimens in overall adverse events (RR, 1.40; 95% CI, 0.90 to 2.21).

### B How do all-oral regimens compare to all-injectable regimens?

We did not find any trials that compared an all-oral regimen to an all-injectable regimen, with or without aprepitant.

### C How do mixed oral and injectable regimens compare?

#### Comparison of mixed oral and injectable regimens, with and without aprepitant

Among the seven RCTs included for comparison of mixed oral and injectable regimens, with and without aprepitant,17–23 all but one trial provided data on harms.19 Four trials reported incidence of overall adverse events17, 18, 20, 22 and provided high-strength evidence (Appendix F) that there is no statistically significant difference between mixed oral and injectable regimens, with or without aprepitant (pooled rates, 71% compared with 69%; RR, 1.03; 95% CI, 0.97 to 1.10). No statistically significant differences between groups with and without aprepitant were reported for any individual adverse events. The most commonly reported events were fatigue/asthenia (range, 9% to 26%) and constipation (range, 8% to 22%).

#### Comparison of mixed oral and injectable regimens of a 5-HT3 antagonist plus a corticosteroid

Only one26 of three RCTs26–28 involving mixed oral and injectable regimens reported rates of overall adverse events. This trial provided a low strength of evidence (Appendix F) that differences were not statistically significantly different between mixed oral and injectable regimens and all-injectable regimens (38% compared with 44%; RR, 0.85; 95% CI, 0.42 to 1.68; Appendix F).26 Similarly, differences between groups were not found for any of the most frequently reported adverse events including headache, diarrhea, and constipation.

### D How do regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy compare to those regimens given for longer periods of time?

The single RCT (N=108) that compared regimens given immediately prior to and for 48 hours after initiation of chemotherapy to those given for longer periods of time provided very sparse data on harms and did not include the incidence of overall adverse events.21 Although this trial found no significant difference between the multi-day aprepitant group compared with the single-day aprepitant group for any specific adverse event, because this trial evaluated a formulation and dose of aprepitant that is unavailable in the United States, this evidence is insufficient for drawing conclusions about the current FDA-recommended dosage regimen for this question.

### E Summary of evidence

The summary of evidence for this Key Question is presented in Table 7, below.

Table 7 Summary of the evidence for Key Question 2

Key Question | Strength of evidence | Conclusions
2.A. How do oral regimens compare to each other? Outcome: Overall adverse events
Comparison of regimens with and without aprepitant | Moderate | No significant differences (RR, 0.93; 95% CI, 0.85 to 1.03).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Low | No significant differences (RR, 1.40; 95% CI, 0.90 to 2.21).
2.B. How do oral regimens compare to injectable regimens?
| Insufficient | No trials included.
2.C. How do mixed oral and injectable regimens compare?
Comparison of regimens with and without aprepitant | High | No significant differences (RR, 1.03; 95% CI, 0.97 to 1.10).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Low | No significant differences (RR, 0.85; 95% CI, 0.42 to 1.68).
2.D. How do regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy compare to those regimens given for longer periods of time?
| Insufficient | Not reported.

## Key Question 3 Are there subgroups of patients based on demographics (age, race, gender), socioeconomic status, other medications, or comorbidities for which one of these antiemetic regimens is more effective or associated with fewer adverse events in the context of emetogenic anticancer chemotherapy and/or radiation?

### A What is the applicability of the evidence to patients age 65 and older?

While older age has been shown to predict lower rates of emesis associated with chemotherapy,31 relative to younger age, the evidence base evaluating comparisons of specific regimens to each other in this age group was somewhat limited. This was due largely to the fact that the majority of patients enrolled in these randomized controlled trials (RCTs) were younger than 65.

Among the RCTs comparing antiemetic regimens of drugs all given by the same route, the median or mean age of patients enrolled was 48,^16^ 53,^13^ and 61.^14^ Of these, the most relevant evidence to patients over 65 years came from a trial comparing an oral three-drug regimen containing aprepitant to an oral two-drug regimen of 5-HT3 antagonist and corticosteroid, with an age range of 23 to 78 years (mean 53 years), where 15% were age 65 or over. For this trial both published and unpublished data were available.13, 32 In the published article, it was stated that there was no interaction between treatment group and age (< 55 years, > 55 years), with the oral three-drug regimen superior to the oral two-drug regimen, but analysis of patients over 65 was not reported.13 Based on unpublished data submitted (Appendix G), multiple regression analysis was reported to show no effect of age on complete response rate between patients over 65 years and less than 65 years (P=0.788) or between patients aged 75 years and over and those less than 75 years (P=0.631). However, this analysis appeared to only address the question of whether complete response rate was affected by age. It did not take the specific antiemetic regimen into account (e.g. the effect on response of an interaction between treatment and age > 65), making a comparison across the two treatment regimens. For complete response (time period not specified) the rates in the group age 65 and over were reported to be 61% with the three-drug regimen compared to 55% with the two-drug regimen.32 Our statistical analysis of these data indicated that the difference between regimens was not statistically significant for the age group 65 and over, but was significant for those under 65 years (Figure 5 below). The lack of a statistically significant finding may be due to inadequate power due to a small sample size (N=129 for age 65 and over compared with N=728 for younger than age 65) or to the fact that this was an unadjusted analysis.

Figure 5 Unadjusted relative risk for complete response by age: Oral three-drug regimen compared with oral two-drug regimen (Warr 2005; unpublished data)

In nine other RTCs comparing mixed oral and intravenous regimens,17–20, 22, 23, 26–29 the mean or median ages ranged from a low of 47 years28 to a high of 62 years;21 however, five of these trials included patients above 70 years.18, 20, 22, 23, 26

In a pooled analysis of patient-level data from two of these trials,20, 22 data were analyzed according to age groups: < 60, 60 to 65, 65 to 70, and > 70 years.33 These trials compared a three-drug regimen to a two-drug regimen, using an intravenous 5-HT3 antagonist and oral dexamethasone in both groups, but the three-drug group also had aprepitant on days 1 to 3, and received lower doses of dexamethasone than the two-drug group (see Evidence Table 1 for details). In this prespecified subgroup analysis, 28% of patients were over 65 years. Analysis of complete response over the period of one to five days after start of chemotherapy indicated that the three-drug regimen was superior to the two-drug regimen in both older (76.1% compared with 54.1%; P<0.001) and younger (63.9% compared with 45.3%; P<0.001) patient groups (Figure 6 below is our analysis based on unpublished data submitted for these two trials). The difference between regimens was greatest for those younger than 60 years and older than 70 years, supporting the finding that older patients experience less emesis than younger patients overall.

Figure 6 Pooled unadjusted relative risk for complete response in patients age 65 and over: Mixed oral and intravenous three-drug regimen compared with two-drug regimen

Cochran Q = 0 (df=1) P>0.9999

I^2^ (inconsistency) = too few studies to estimate

Unpublished data were submitted for a third trial that had a higher proportion of patients age 65 and over (32%).23, 32 The regimens compared in this trial were ondansetron on days 1 to 4 and dexamethasone on days 1 to 4, compared with aprepitant on days 1 to 3, ondansetron on day 1, and dexamethasone on days 1 to 4, rather than a comparison of ondansetron on day 1 only, as in the trials above. Similar to our unadjusted analysis presented above of unpublished data submitted for a trial of an all-oral regimen, our analysis here did not find a significant difference in complete response among older patients (RR, 1.13; 95% CI, 0.94 to 1.38), while the analysis of data for younger patients indicated a statistically significant benefit for the three-drug regimen (RR, 1.22; 95% CI, 1.03 to 1.45).

Based on these RCTs, aprepitant-containing regimens were superior to regimens without aprepitant in rates of complete response over the entire treatment period in patients over 65 years where the comparison treatment administered the 5-HT3 antagonist on day 1 only. For comparisons of oral regimens, or mixed regimens where the two drug regimen included administration of a 5-HT3 antagonist through day 4, no benefit was found with a three-drug regimen. There was no evidence evaluating the comparative harms of these regimens in patients 65 and over, or evaluating other outcomes. The strength of this evidence was moderate, largely because of the risk of bias resulting from a pooled analysis including data from two of nine possible trials making comparisons of mixed oral and intravenous regimens, only one trial of regimens given by the same route, and no evidence on comparative harms. Further research may change our confidence in the estimate of effect and may change the estimate.

### B Is there evidence of disparate effects on age, gender, socioeconomic status, or ethnicity/race?

#### Age

Differences in outcome based on age have not been well studied, as discussed above.

#### Gender

Female gender has long been known to be associated with higher rates of chemotherapy-induced nausea and emesis.31 The evaluation of gender in the trials in this report focused on the evidence of a difference in response between regimens based on gender. Most participants in the three RCTs comparing regimens given by a single route were women, with the two trials of aprepitant oral three-drug regimens compared to oral 5-HT3 antagonist two-drug regimens in women with breast cancer receiving cisplatin-based chemotherapy regimens.13, 14 The third trial compared two oral 5-HT3 antagonist/corticosteroid regimens and enrolled 67% female participants. Analysis of effects based on gender was not undertaken.

Eleven other RCTs compared mixed oral and intravenous regimens. Two of these 11 trials undertook analyses of the effect of gender on response20, 22 and were subsequently included in two pooled analysis of patient-level data.33, 34 Both trials compared aprepitant-containing regimens to a 5-HT3 antagonist/corticosteroid regimen in patients receiving cisplatin-based chemotherapy and found the aprepitant regimen to be superior over a six-day period. While logistic regression indicated that women had lower response rates to the two-drug regimen compared with men in one trial (39% compared with 61%),20 neither trial found the differences between men and women to be qualitatively significant using the Gail and Simon test, such that they felt combining these data in analyses was justified. Neither trial found differences in complete response based on gender for the aprepitant (three-drug) regimens. Because of these findings, an analysis of the results of these similar trials examining the effects of gender was undertaken.33, 34 In these analyses, 42% (435/1043) of the patients were women and the rate of complete response across treatments was higher among men (61%) than women (53%). A difference between women and men was maintained when the data were evaluated by treatment group. In comparison to the two-drug regimen, the aprepitant-containing regimen resulted in a difference of 25% in complete response over five days in women (our calculation of unadjusted relative risk, 1.65; 95% CI, 1.37 to 2.00) while the difference among men was 16% (our calculation of unadjusted relative risk, 1.30; 95% CI, 1.14 to 1.48). Similar differences were found with results in the acute and delayed phases. Female sex has been known to be a risk factor for chemotherapy induced nausea and vomiting, and in this analysis women benefited similarly but to a greater absolute amount than men from a three-drug aprepitant regimen.

The strength of this evidence was moderate largely because of the risk of bias resulting from a pooled analysis including data from two of eleven possible RCTs making comparisons of mixed oral and intravenous regimens, none of regimens given by the same route, and no evidence on comparative harms. Further research may change our confidence in the estimate of effect and may change the estimate.

#### Socioeconomic status

No evidence on socioeconomic status was provided by the trials.

#### Race

Of the three RCTs comparing antiemetic regimens of drugs all given by the same route, one reported that 80% of patients were white,13 and a second, smaller, trial was conducted entirely with ethnic Chinese patients.14 These studies were similar, and compared a 5-HT3 antagonist/corticosteroid regimen with the same regimen plus aprepitant. In the larger trial of mostly white patients, the analysis was adjusted for race. This trial also conducted a separate analysis of factors including race, and found no interaction between treatment (oral three-drug regimen or oral two-drug regimen) response and race. Given the high proportion of white patients and the lack of details on other races included, these findings should be considered preliminary. Although conducted in racially different populations, both trial results indicated that the aprepitant-containing regimen was superior in both acute and delayed outcomes. However, small differences were noted in adverse event rates and neither trial was designed to assess these outcomes properly. The third trial did not report the race of enrolled patients.16

Eleven other RCTs comparing mixed oral and intravenous regimens included a variety of races in their enrolled patient populations, including Asian, Black, Hispanic, white, and “other.” Analysis of outcome by race was not undertaken in any trial.

### C Are certain groups more likely to receive one treatment over another, due to prescription trends in a geographic region, socioeconomic status, health insurance coverage, etc.?

Five fair-to-poor quality cohort studies of 3050 patients provided limited evidence to evaluate factors that influence the selection of specific antiemetic regimens.35–39 Four of these studies found that among patients receiving primarily moderate to highly emetogenic single-day chemotherapy regimens, the choice of antiemetic regimen was not associated significantly with the patient’s prior experience with chemotherapy induced nausea and vomiting.36–39 These analyses did not, however, report results stratified by individual 5-HT3 antagonist drug and did not include aprepitant at all. Two studies also reported that there was also no association with choice of regimen and patient age, sex, or alcohol use.35, 38 Only one of these studies reported specific 5-HT3 antagonist drugs: ondansetron, granisetron, and dolasetron (all given with dexamethasone).35 This study also did not find association with baseline Eastern Cooperative Oncology Group performance status. No evidence on prescription trends based on geographic region, socioeconomic status, or health insurance coverage was found.

The strength of this body of evidence was low, in that future, higher-quality studies with specific focus on these issues could change these findings (Appendix F). The currently available evidence has somewhat limited applicability. It primarily relates to patients receiving moderate to highly emetogenic chemotherapy given on a single day in inpatient or outpatient setting, and includes a variety of cancers with breast, colorectal, and lung cancer being the most common. It does not have applicability to the use of aprepitant or palonosetron.

### D Summary of evidence

The summary of evidence for this Key Question is presented in Table 8, below.

Table 8 Summary of the evidence for Key Question 3

Key Question | Strength of evidence | Conclusions
3.A. What is the applicability of the evidence to patients age 65 and older?
How do oral regimens compare to each other?
Comparison of regimens with and without aprepitant | Complete Response Overall: Low | No significant difference in patients 65 and over (RR, 1.11; 95% CI, 0.82 to 1.51); difference significant in younger patients (RR, 1.21; 95% CI, 1.03 to 1.43).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Insufficient | Subgroup analyses not available.
How do mixed oral and injectable regimens compare?
Comparison of regimens with and without aprepitant | Complete Response: Overall Treatment Period Moderate | Modest benefit with three-drug regimen (RR, 1.39; 95% CI, 1.17 to 1.64) compared with two-drug regimens administering a 5-HT3 antagonist on day 1 only. Compared with RR, 1.41; 95% CI, 1.23 to 1.62) in patients less than 65.
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Insufficient | Subgroup analyses not available.
Other outcomes, including harms have not been adequately evaluated in patients 65 and over
3.B. Is there evidence of disparate effects on age, gender, socioeconomic status, or ethnicity/race? | Gender
How do oral regimens compare to each other?
Comparison of regimens with and without aprepitant | Complete Response High | Two of three trials included 99% to 100% women, the third enrolled 67% women. Results indicate modest a benefit for three-drug regimen (RR, 1.45; 95% CI, 1.32 to 1.60).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Insufficient | Subgroup analyses not available.
How do mixed oral and injectable regimens compare?
Comparison of regimens with and without aprepitant | Complete Response: Overall Treatment Period Moderate | Three-drug regimen found superior to two-drug regimen, with larger effect in women than men (RR, 1.65; 95% CI, 1.37 to 2.00 in women compared with RR, 1.30; 95% CI, 1.14 to 1.48 in men).
Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid | Insufficient | Subgroup analyses not available
Other outcomes, including harms have not been adequately evaluated in women.
Other subgroups, including race, ethnicity, and socioeconomic status have not been adequately studied to make conclusions.
3.C. Are certain groups more likely to receive one treatment over another, due to prescription trends in a geographic region, socioeconomic status, health insurance coverage, etc.? | Low | Choice of antiemetic regimen was not associated with the patient’s prior experience with chemotherapy induced nausea and vomiting, age, sex, alcohol use, or baseline performance status.

Abbreviations: RCT, randomized controlled trial.