# METHODS

This report on the comparative benefits and harms of antiemetic regimens that consist of a 5-hydroxytryptamine-3 (5-HT3) antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation, was based on a systematic review of the literature. The approach, methodology, and criteria used were agreed upon by consensus of staff at the Oregon Evidence-based Practice Center (Oregon EPC), Centers for Medicare & Medicaid Services (CMS), and the Agency for Healthcare Research and Quality (AHRQ).

## Search Strategy

In October 2009, in consultation with a medical librarian, we conducted a comprehensive search of the scientific literature to identify relevant citations addressing the Key Questions of this technology assessment. For Key Questions 1a through 3b, we searched MEDLINE^®^ and the third Quarter 2009 Cochrane databases (Central Register of Controlled Trials, Database of Systematic Reviews, Database of Abstracts of Reviews of Effects) from October 2009 back to October 2008 using included drugs, indications, and study designs as search terms (see Appendix C for complete search strategies). For identification of citations between 1966 and October 2008, we relied on the previous searches done for the Drug Effectiveness Review Project (DERP) Drug Class Review on Newer Antiemetics. For Key Question 3c, which was not included in the scope of the DERP Drug Class Review on Newer Antiemetics, we conducted a new search of MEDLINE^®^ (1966 through January 2010) and the first Quarter 2010 Cochrane databases (Central Register of Controlled Trials, Database of Systematic Reviews, and Database of Abstracts of Reviews of Effects). References of included studies were screened for any studies that may have met inclusion but were not identified through other means.

## Study Selection

Using the criteria listed below, two reviewers assessed abstracts of citations identified from literature searches for inclusion. Full-text articles of potentially relevant abstracts were retrieved, and a second review for inclusion was conducted by two reviewers reapplying the inclusion criteria. Disagreements in inclusion decisions were resolved through consensus.

### Populations

Adults at risk for or with nausea, vomiting (including retching), or both, related to the following therapies and conditions:

- Chemotherapy of various emetogenicity
- Radiation therapy

For classification of chemotherapy emetic risk, we used the descriptions as reported in the individual trial publications (e.g., high, moderate, etc.). When the emetogenic potential was not explicitly stated, we referred to the four-level classification system revised by the Multinational Association of Supportive Care in Cancer (MASCC) in 2009 (high, moderate, low, minimal).4 In this system, for example, chemotherapeutic agents rated as having a “high” degree of emetogenicity have a 90% incidence of emesis (i.e., cisplatin) and those rated as “moderate” have a 30% to 90% incidence of emesis (i.e., carboplatin).

### Interventions

In accordance with the specific programmatic interests of CMS, eligibility of interventions was assessed based the antiemetic regimen in its entirety. Included studies involved either a three-drug regimen including aprepitant, a 5-HT3 antagonist (e.g., dolasetron, granisetron, ondansetron, palonosetron), and a corticosteroid (e.g., dexamethasone, prednisone), or a two-drug regimen including a 5-HT3 antagonist and a corticosteroid. The primary focus of the report is to compare all oral regimens to each other, to compare all oral regimens to all intravenous regimens, and to compare mixed oral and intravenous regimens. Studies comparing two regimens in which all drugs are given intravenously were excluded. Formulations of aprepitant and the 5-HT3 antagonists are shown in Table 1. Based on consideration of the collective form and routs of all the drugs combined, regimens were classified as either all-oral, all-intravenous, or containing mixed oral and intravenous drugs. We excluded studies that used a 5-HT3 antagonist alone or in combination with another non-corticosteroid drug (e.g., metoclopramide, lorazepam, etc.) and in which the dosage form or route of the corticosteroid was variable, unclear, or both.

### Effectiveness outcomes

The following outcomes were evaluated during the acute (during the first 24 hours of chemotherapy administration) or delayed phases (after the first 24 hours of chemotherapy administration):

- Total control (e.g., no emesis, no use of rescue medication, no or mild nausea)
- Complete response (e.g., no emesis, no use of rescue medication)
- No emesis
- No nausea
- Ability to tolerate sequential chemotherapy sessions
- Quality-of-life measures

Wherever possible, data on effective dose range, dose response, and duration of therapy (time to success) was evaluated within the context of comparative effectiveness.

### Harms

- Overall adverse events
- Specific adverse events (headache, constipation, dizziness, sedation, etc)
- Withdrawals due to adverse events
- Serious adverse events

### Study designs

For effectiveness: controlled clinical trials and good-quality systematic reviews. For harms: controlled clinical trials and observational studies.

## Data Abstraction

The following data were abstracted from included trials: study design; setting; population characteristics including sex, age, ethnicity, and diagnosis; eligibility and exclusion criteria; interventions (dose and duration); comparisons; numbers screened, eligible, enrolled, and lost to follow-up; method of outcome ascertainment; and results for each outcome. We recorded intention-to-treat results when reported. If true intention-to-treat results were not reported, but loss to follow-up was very small (≤ 5%), we considered these results to be intention-to-treat results. In cases where only per protocol results were reported, we calculated intention-to-treat results if the data for these calculations were available. If such calculations were made, they were noted. Data abstraction was performed by one reviewer and independently checked by a second reviewer.

## Validity Assessment

We assessed the internal validity (quality) of trials based on the predefined criteria listed in Appendix D. These criteria are based on the US Preventive Services Task Force and the National Health Service Centre for Reviews and Dissemination (United Kingdom) criteria.5, 6 We rated the internal validity of each trial based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; adequate reporting of dropouts, attrition, crossover, adherence, and contamination; loss to follow-up; and the use of intention-to-treat analysis. Trials that had a fatal flaw were rated poor quality, trials that met all criteria were rated good quality, and the remainder were rated fair quality. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others are only possibly valid. A poor-quality trial is not valid; the results are at least as likely to reflect flaws in the study design as a true difference between the compared drugs. A fatal flaw is reflected by failure to meet combinations of items of the quality assessment checklist. A particular randomized trial might receive two different ratings, one for effectiveness and another for adverse events.

Appendix D also shows the criteria we used to rate observational studies of adverse events. These criteria reflect aspects of the study design that are particularly important for assessing adverse event rates. We rated observational studies as good quality for adverse event assessment if they adequately met six or more of the seven predefined criteria, fair quality if they met three to five criteria, and poor quality if they met two or fewer criteria.

Included systematic reviews were also rated for quality (Appendix D). We rated the internal validity based a clear statement of the questions(s); reporting of inclusion criteria; methods used for identifying literature (the search strategy), validity assessment, and synthesis of evidence; and details provided about included studies. Again, these studies were categorized as good when all criteria were met.

## Grading Strength of Evidence

We graded strength of evidence based on the guidance established for the Evidence-based Practice Center Program of the Agency for Healthcare Research and Quality.7 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias.

Table 2 describes the grades of evidence that can be assigned. Grades reflect the strength of the body of evidence to answer key questions on the comparative efficacy, effectiveness, and harms of 5-HT3 antagonists, with or without aprepitant. Grades do not refer to the general efficacy or effectiveness of pharmaceuticals.

Table 2 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Sources: 8

Among the multitude of outcomes assessed in trials of antiemetics, we focused on rating the strength of evidence for only a subset of four that we judged to represent the most clinically important and reliable: total control, complete response, ability to tolerate sequential chemotherapy sessions, and overall adverse events. Complete response was the most commonly reported composite outcome and is typically defined as no emetic episodes and no use of rescue medication. Complete response was used by the American Society of Clinical Oncology in their 2006 update of their guideline for antiemetics in oncology and was recommended as a standard primary endpoint for clinical trials.3 Total control is typically defined as no vomiting, no use of rescue medication, and none to mild nausea. Although total control is a less commonly reported outcome and includes patient subjectivity with regard to the component of nausea, we emphasize its importance in this review as we believe the fewest number of overall symptoms represents the maximal patient outcome and optimal goal of antiemetic therapy. We agree, however, that as an individual outcome, the subjective perception of nausea as judged only by the patient is, by nature, less reliable, and we have not discussed the results of this outcome in this report.

## Applicability

The applicability of each body of evidence considered in this report was discussed. Particular attention was paid to whether the evidence was applicable to patients 65 years of age and older.

## Data Synthesis

We constructed evidence tables showing the study characteristics, quality ratings, and results for all included studies. We reviewed studies using a hierarchy of evidence approach, and the best evidence was the focus of our synthesis for each question, population, intervention, and outcome addressed. Studies that evaluated one antiemetic regimen against another provided direct evidence of comparative effectiveness and adverse event rates and were the focus of this review. As discussed in more detail above under “Grading Strength of Evidence”, the composite outcomes of total control (no emetic events, no rescue medication, none to mild nausea) and complete response (no emetic events, no rescue medication) were preferred to the individual outcomes of no emesis and no nausea.

Quantitative analyses were conducted where possible. We used Stats Direct (version 2.7.7, 9/13/2009) to perform meta-analyses of outcomes reported by a sufficient number of studies that were homogeneous enough that combining their results could be justified. In order to determine whether meta-analysis could be meaningfully performed, we considered the quality of the studies and the heterogeneity among studies in design, patient population, interventions, and outcomes. When meta-analysis could not be performed, the data were summarized qualitatively.

Random-effects models9 were used to estimate pooled relative risks and their 95% confidence intervals. We used Forest plots to graphically summarize results of individual studies and of the pooled analysis.10 The Q statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess heterogeneity in effects between studies.11, 12 Potential sources of heterogeneity were examined by analysis of subgroups of study design, study quality, patient population, and variation in interventions.

## Peer Review and Public Comment

We requested and received peer review of the report from three sources. Comments were reviewed, and where possible, incorporated into the final document. The draft report was also posted to the AHRQ website for public comment. We received comments from one pharmaceutical company and one professional organization.