# INTRODUCTION

Nausea and vomiting are common symptoms in cancer patients undergoing chemotherapy and radiation therapy. In some cases, failure to control nausea and vomiting in cancer patients may result in reduced nutritional status and quality of life and may prompt refusal for continuation of chemotherapeutic and radiation therapy cycles.1, 2

Many types of neuroreceptors are believed to be involved in the development of nausea and vomiting, including serotonin (5-hydroxytryptamine-3 [5-HT3]), dopamine, corticosteroid, and substance P/neurokinin 1 (NK1).2 Although a variety of older drugs have been used to prevent and treat chemotherapy induced nausea and vomiting in the past (for example, metoclopramide), these drugs were less selective for the receptors found to be involved in nausea and vomiting, resulting in lower than acceptable response and higher than acceptable rates of side effects. Therefore, antiemetic agents have been developed to target specific neuroreceptors and can be used in combination with one another. The 5-HT3 antagonists (e.g., dolasetron, granisetron, ondansetron, or palonosetron) and aprepitant (a neurokinin 1 receptor antagonist) were developed specifically to treat and prevent nausea and vomiting and are the most commonly used drugs today.

The intravenous dosage form of ondansetron was the first 5-HT3 antagonist to be approved by the US Food and Drug Administration (FDA) in 1991, and oral aprepitant was approved in 2003. The two-drug combination of a 5-HT3 antagonist plus dexamethasone (a corticosteroid) and the three-drug combination of aprepitant, a 5-HT3 antagonist, and dexamethasone are now the most commonly used regimens and are supported by the current American Society of Clinical Oncology guideline for antiemetics in oncology.3 Table 1 outlines the FDA-approval status of these drugs for use in managing nausea and vomiting in cancer patients and Appendix A provides dosages recommended by the FDA.

Table 1 Antiemetic drug indications approved by the US Food and Drug Administration

Drug (brand name) | Dosage form^a^ | Moderately and highly emetogenic chemotherapy | Radiation
Aprepitant/Fosaprepitant (Emend) | Oral capsule | X
Aprepitant/Fosaprepitant (Emend) | Injection | X
Dolasetron (Anzemet) | Oral tablet | X^a^
Dolasetron (Anzemet) | Injection | X
Granisetron (Kytril) (Sancuso) | Oral tablet | X | X
Granisetron (Kytril) (Sancuso) | Injection | X
Granisetron (Kytril) (Sancuso) | Film, extended release, transdermal | X
Ondansetron (Zofran) | Injection | X
Ondansetron (Zofran) | Oral tablet, solution | X | X
Ondansetron (Zofran) | Oral solution | X | X
Palonosetron (Aloxi) | Injection | X

a Only approved by the FDA for moderately emetic chemotherapy.

## Purpose of the Report

The Social Security Act sets forth specific statutory requirements under which oral aprepitant and 5-HT3 antagonist drugs are a benefit in the fee-for-service Medicare program. Medicare may provide coverage for oral aprepitant and 5-HT3 antagonists (1) when used as a full therapeutic replacement for intravenous dosage forms and (2) when administered immediately before, at, or within 48 hours after the time of administration of the chemotherapeutic agent or the radiation therapy. Medicare has received comments suggesting changes to the policy regarding the coverage for these oral antiemetic drugs. This led to interest in a Technology Assessment of the comparative benefits and harms between and among oral and intravenous treatment regimens of antiemetics, specifically two-drug and three-drug regimens consisting of a 5-HT3 antagonist and a corticosteroid, with or without aprepitant. Therefore, the Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Oregon Evidence-based Practice Center (Oregon EPC) (Contract #I HHSA 290-2007-10057-1).

The objective of the report is to evaluate the comparative overall benefits and harms of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic chemotherapy and/or radiation. Special attention will be given to how they affect outcomes in the Medicare population (i.e., people at least 65 years old). The main focus is on comparing regimens given by all-oral or all-intravenous routes and all-oral regimens compared to each other. The specific questions addressed are described at the end of the Introduction section.

This technology assessment report builds upon portions of previous work conducted by the Oregon EPC; a systematic review of the comparative effectiveness and harms of 5-HT3 antagonists and aprepitant in children and adults for prevention/treatment of nausea and vomiting associated with surgical procedures, chemotherapeutic agents, radiation therapy, and pregnancy, for the Drug Effectiveness Review Project (DERP) (http://derp.ohsu.edu/final/Antiemetics_final_report_update%201_JAN_091.pdf).

## Key Questions

CMS requested an evaluation of the comparative overall benefits of antiemetic regimens that consisted of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation. Specifically, they posed the following questions for review:

1. What are the comparative overall benefits of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation? Outcomes of interest include (at least): ability to control nausea and vomiting; ability to tolerate sequential chemotherapy sessions; quality of life measures
  a. How do all-oral regimens compare to each other?
  b. How do all-oral regimens compare to all-injectable regimens?
  c. How do mixed oral and injectable regimens compare?
  d. How do regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy compare to those regimens given for longer periods of time?
2. What are the harms of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation?
  a. How do all-oral regimens compare to each other?
  b. How do all-oral regimens compare to all-injectable regimens?
  c. How do mixed oral and injectable regimens compare?
  d. How do regimens given immediately prior to and/or for 48 hours after initiation of starting the chemotherapy regimen compare to those regimens given for longer periods of time?
3. Are there subgroups of patients based on demographics (age, race, gender), socioeconomic status, other medications, or comorbidities for which one of these antiemetic regimens is more effective or associated with fewer adverse events in the context of emetogenic anticancer chemotherapy and/or radiation?
  a. What is the applicability of the evidence to patients age 65 and older?
  b. Is there evidence of disparate effects based on age, gender, socioeconomic status, or ethnicity/race?
  c. Are certain groups more likely to receive one treatment over another, due to prescription trends in a geographic region, socioeconomic status, health insurance coverage, etc.?

## Purpose and Limitations of Systematic Reviews

Systematic reviews, also called evidence reviews, are the foundation of evidence-based practice. They focus on the strength and limits of evidence from studies about the effectiveness of a clinical intervention. Systematic reviews begin with careful formulation of research questions. The goal is to select questions that are important to patients and clinicians then to examine how well the scientific literature answers those questions. Terms commonly used in systematic reviews, such as statistical terms, are provided in Appendix B.

Systematic reviews emphasize the patient’s perspective in the choice of outcome measures used to answer research questions. Studies that measure health outcomes (events or conditions that the patient can feel, such as fractures, functional status, and quality-of-life) are preferred over studies of intermediate outcomes (such as change in bone density). Reviews also emphasize measures that are easily interpreted in a clinical context. Specifically, measures of absolute risk or the probability of disease are preferred to measures such as relative risk. The difference in absolute risk between interventions depends on the number of events in each group, such that the difference (absolute risk reduction) is smaller when there are fewer events. In contrast, the difference in relative risk is fairly constant between groups with different baseline risks for the event, such that the difference (relative risk reduction) is similar across these groups. Relative risk reduction is often more impressive than absolute risk reduction. Another useful measure is the number needed to treat (or harm). The number needed to treat is the number of patients who would need be treated with an intervention for one additional patient to benefit (experience a positive outcome or avoid a negative outcome). The absolute risk reduction is used to calculate the number needed to treat.

Systematic reviews weigh the quality of the evidence, allowing a greater contribution from studies that meet high methodological standards and, thereby, reducing the likelihood of biased results. In general, for questions about the relative benefit of a drug, the results of well-executed randomized controlled trials are considered better evidence than results of cohort, case-control, and cross-sectional studies. In turn, these studies provide better evidence than uncontrolled trials and case series. For questions about tolerability and harms, observational study designs may provide important information that is not available from controlled trials. Within the hierarchy of observational studies, well-conducted cohort designs are preferred for assessing a common outcome. Case-control studies are preferred only when the outcome measure is rare and the study is well conducted.

Systematic reviews pay particular attention to whether results of efficacy studies can be generalized to broader applications. Efficacy studies provide the best information about how a drug performs in a controlled setting. These studies attempt to tightly control potential confounding factors and bias; however, for this reason the results of efficacy studies may not be applicable to many, and sometimes to most, patients seen in everyday practice. Most efficacy studies use strict eligibility criteria that may exclude patients based on their age, sex, adherence to treatment, or severity of illness. For many drug classes, including the antipsychotics, unstable or severely impaired patients are often excluded from trials. In addition, efficacy studies frequently exclude patients who have comorbid disease, meaning disease other than the one under study. Efficacy studies may also use dosing regimens and follow-up protocols that are impractical in typical practice settings. These studies often restrict options that are of value in actual practice, such as combination therapies and switching to other drugs. Efficacy studies also often examine the short-term effects of drugs that in practice are used for much longer periods. Finally, efficacy studies tend to assess effects by using objective measures that do not capture all of the benefits and harms of a drug or do not reflect the outcomes that are most important to patients and their families.

Systematic reviews highlight studies that reflect actual clinical effectiveness in unselected patients and community practice settings. Effectiveness studies conducted in primary care or office-based settings use less stringent eligibility criteria, more often assess health outcomes, and have longer follow-up periods than most efficacy studies. The results of effectiveness studies are more applicable to the “average” patient than results from the highly selected populations in efficacy studies. Examples of effectiveness outcomes include quality-of-life, frequency or duration of hospitalizations, social function, and the ability to work. These outcomes are more important to patients, family, and care providers than surrogate or intermediate measures, such as scores based on psychometric scales.

Efficacy and effectiveness studies overlap. For example, a study might use very narrow inclusion criteria like an efficacy study, but, like an effectiveness study, might examine flexible dosing regimens, have a long follow-up period, and measure quality-of-life and functional outcomes. For this report we sought evidence about outcomes that are important to patients and would normally be considered appropriate for an effectiveness study. However, many of the studies that reported these outcomes were short term and used strict inclusion criteria to select eligible patients. For these reasons, it was neither possible nor desirable to exclude evidence based on these characteristics. Labeling a study as either an efficacy or an effectiveness study, although convenient, is of limited value; it is more useful to consider whether the patient population, interventions, time frame, and outcomes are relevant to one’s practice or to a particular patient.

Studies anywhere on the continuum from efficacy to effectiveness can be useful in comparing the clinical value of different drugs. Effectiveness studies are more applicable to practice, but efficacy studies are a useful scientific standard for determining whether characteristics of different drugs are related to their effects on disease. Systematic reviews thoroughly cover the efficacy data in order to ensure that decision makers can assess the scope, quality, and relevance of the available data. This thoroughness is not intended to obscure the fact that efficacy data, no matter how large the quantity, may have limited applicability to practice. Clinicians can judge the relevance of studies’ results to their practice and should note where there are gaps in the available scientific information.

Unfortunately, for many drugs there exist few or no effectiveness studies and many efficacy studies. Yet clinicians must decide on treatment for patients who would not have been included in controlled trials and for whom the effectiveness and tolerability of the different drugs are uncertain. Systematic reviews indicate whether or not there exists evidence that drugs differ in their effects in various subgroups of patients, but they do not attempt to set a standard for how results of controlled trials should be applied to patients who would not have been eligible for them. With or without an evidence report, these decisions must be informed by clinical judgment.

In the context of development of recommendations for clinical practice, systematic reviews are useful because they define the strengths and limits of the evidence, clarifying whether assertions about the value of an intervention are based on strong evidence from clinical studies. By themselves, they do not say what to do. Judgment, reasoning, and applying one’s values under conditions of uncertainty must also play a role in decision making. Users of an evidence report must also keep in mind that not proven does not mean proven not; that is, if the evidence supporting an assertion is insufficient, it does not mean the assertion is untrue. The quality of the evidence on effectiveness is a key component, but not the only component, in making decisions about clinical policy. Additional criteria include acceptability to physicians and patients, potential for unrecognized harm, applicability of the evidence to practice, and consideration of equity and justice.