# EXECUTIVE SUMMARY

## Background

Nausea and vomiting are common symptoms in cancer patients undergoing chemotherapy and radiation therapy. In some cases, failure to control nausea and vomiting in cancer patients may result in reduced nutritional status and quality of life, and may prompt the refusal of continuing chemotherapeutic and radiation therapy cycles. The benefits and harms of antiemetic regimens including a 5-hydroxytryptamine-3 (5-HT3) antagonist and a corticosteroid, with and without aprepitant, have been researched in many clinical studies. However, these antiemetic regimens need to be evaluated in the context of the specific programmatic interests of Centers for Medicare & Medicaid Services in terms of all-oral regimens compared with one another, all-oral regimens compared to all-injectable regimens, and mixed oral compared with injectable regimens. Additionally, the applicability of the evidence to patients age 65 and older needs to be determined.

## Methods

This report compares the benefits and harms of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation, and is based on a systematic review of the literature. The approach, methodology, and criteria used were agreed upon by consensus of staff at the Oregon Evidence-based Practice Center (EPC), Centers for Medicare & Medicaid Services (CMS), and the Agency for Healthcare Research and Quality (AHRQ). We assessed the internal validity (quality) of all studies based on predefined criteria. We graded the overall strength of evidence based on the guidance established for the Evidence-based Practice Center Program of AHRQ. The composite outcomes of total control (no emetic events, no rescue medication, none to mild nausea) and complete response (no emetic events, no rescue medication) were preferred to the individual outcomes of no emesis and no nausea. Applicability of the evidence was considered, with particular attention paid to whether the evidence was applicable to patients 65 years of age and older. Quantitative analyses were conducted where possible using Stats Direct (version 2.7.7, 9/13/2009). Random-effects models were used to estimate pooled relative risks and their 95% confidence intervals.

## Results

### Key Question 1 What are the comparative overall benefits of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation? Outcomes of interest include (at least): ability to control nausea and vomiting; ability to tolerate sequential chemotherapy sessions; quality of life measures

#### Comparison of oral regimens

##### Comparison of regimens with and without aprepitant

Evidence consisted of three fair-quality randomized controlled trials (RCTs) in adults undergoing moderately emetogenic chemotherapy. For the optimal patient outcome of total control, there was only low-strength evidence of no significant differences between all-oral regimens, with or without aprepitant, for the overall (RR, 0.84; 95% CI, 0.48 to 1.47), acute (RR, 0.94; 95% CI, 0.68 to 1.30) and delayed (RR, 0.82; 95% CI, 0.57 to 1.17) study periods. For complete response, there was predominantly high-strength evidence indicating a significant increase in benefit with three-drug regimens containing aprepitant compared to two-drug regimens without aprepitant during the overall (RR, 1.22; 95% CI, 1.12 to 1.33; high-strength evidence), acute (RR, 1.11; 95% CI, 1.06 to 1.16; moderate-strength evidence), and delayed periods (RR, 1.15; 95% CI, 1.06 to 1.24; high-strength evidence). There was moderate-strength evidence that an all-oral, three-drug, aprepitant-containing regimen resulted in significantly fewer Chinese women undergoing moderately emetogenic chemotherapy to delay subsequent chemotherapy sessions, but it was unclear how applicable these findings are to broader populations.

##### Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid, without aprepitant

Evidence consisted of one fair-quality RCT in adults undergoing moderately emetogenic chemotherapy. The strength of the evidence was low that the proportion of patients who experienced total control of nausea and emesis over 24 hours after starting chemotherapy was not statistically significantly different between the group taking oral granisetron plus oral dexamethasone and the group taking ondansetron plus oral dexamethasone (RR, 1.02; 95% CI, 0.58 to 1.76). Evidence was insufficient to draw conclusions about other outcomes (total control during the delayed period, complete response, ability to tolerate sequential chemotherapy sessions, and quality of life).

#### Comparison of oral regimens to injectable regimens

We did not find any trials that compared an all-oral regimen to an all-injectable regimen, with or without aprepitant.

#### Comparison of mixed oral and injectable regimens

##### Comparison of regimens with and without aprepitant

Evidence consisted of eight fair-quality RCTs in adults undergoing primarily highly emetogenic chemotherapy. For the maximal patient outcome of total control (no emesis, no use of rescue medication, no or mild nausea), there was high-strength evidence of a significant increase with mixed oral and injectable three-drug regimens containing aprepitant compared with two-drug regimens without aprepitant during the overall study period (RR, 1.30; 95% CI, 1.10 to 1.54), as well as during both the acute (RR, 1.12; 95% CI, 1.03 to 1.21) and delayed (RR, 1.36; 95% CI, 1.11 to 1.67) treatment periods in adults undergoing highly emetogenic chemotherapy. High-strength evidence also indicated a significant benefit for the three-drug, aprepitant-containing regimen for complete response (no emesis, no use of rescue medication) during the overall (RR, 1.45; 95% CI, 1.32 to 1.60), acute (RR, 1.15; 95% CI, 1.10 to 1.21), and delayed (RR, 1.43; 95% CI, 1.31 to 1.56) study periods. However, for both outcomes, the benefit of a multi-day, three-drug, aprepitant-containing regimen was minimal during the acute period (a 12% increase) and only became larger in magnitude during the overall and delayed periods when the control group was administered the 5-HT3 antagonist on day 1 only. Greater proportions of patients in the three-drug, aprepitant-containing regimens reported minimal or no impact of chemotherapy-induced nausea and vomiting on quality of life (RR, 1.16; 95% CI, 1.07 to 1.26). Evidence on ability to tolerate sequential chemotherapy sessions was limited to a pooled analysis of data from the extension phases of two short-term trials, which found no significant difference in the rate of study discontinuations between mixed, oral, and injectable three-drug aprepitant-containing regimens and two-drug regimens without aprepitant. However, because the trial discontinuations could have been due to any reason this evidence did not represent a direct link between these treatments and the specific outcome of interest, and the strength of this evidence was low.

##### Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid, without aprepitant

Evidence consisted of three fair-quality RCTs in adults undergoing moderate to highly emetogenic chemotherapies. The outcomes of total control and ability to tolerate sequential chemotherapy sessions were not found in any trials. Low-strength evidence found no statistically significant differences in complete response between different mixed oral and intravenous regimens of a 5-HT3 antagonist and dexamethasone in the overall study period (RR, 0.97; 95% CI, 0.88 to 1.07), the acute period (RR, 0.97; 95% CI, 0.88 to 1.07), or the delayed period (RR, 1.00; 95% CI, 0.60 to 1.66).

#### Comparison of regimens given immediately prior to and/or for 48 hours after initiation of chemotherapy with those regimens given for longer periods of time

We did not find any evidence relating to formulations of included drugs approved by the US Food and Drug Administration (FDA).

### Key Question 2 What are the harms of antiemetic regimens that consist of a 5-HT3 antagonist plus a corticosteroid, with or without aprepitant, given to prevent and/or treat nausea and/or vomiting caused by emetogenic anticancer chemotherapy and/or radiation?

#### Comparison of regimens with and without aprepitant

No significant differences were found between any regimens in incidences of overall adverse events for three-drug, aprepitant-containing regimens compared with two-drug regimens without aprepitant, both when all-oral regimens were compared in patients undergoing moderately emetogenic chemotherapy (RR, 0.93; 95% CI, 0.85 to 1.03; moderate-strength evidence) and when mixed oral and intravenous regimens were compared in patients undergoing highly emetogenic chemotherapy (RR, 1.03; 95% CI, 0.97 to 1.10; high-strength evidence).

#### Comparison of regimens of a 5-HT3 antagonist plus a corticosteroid, without aprepitant

There was only low-strength evidence of no significant differences in incidence of overall adverse events between different two-drug regimens, without aprepitant, regardless of whether they were all given orally (RR, 1.40; 95% CI, 0.9 to 2.21) or using a mixed oral and intravenous regimen (RR, 0.85; 95% CI, 0.42 to 1.68).

### Key Question 3 Are there subgroups of patients based on demographics (age, race, gender), socioeconomic status, other medications, or comorbidities, for which one of these antiemetic regimens is more effective or associated with fewer adverse events in the context of emetogenic anticancer chemotherapy and/or radiation?

#### Applicability of the evidence to patients age 65 and older?

While older age has been shown to be associated with lower rates of nausea and vomiting associated with highly or moderately emetogenic chemotherapy, the likelihood that the findings reported above – directly comparing antiemetic regimens – are broadly applicable to patients age 65 and older is still somewhat limited. The mean or median ages in the studies ranged from a low of 47 years to a high of 62 years, with less than one-third of enrolled patients being age 65 and over.

For comparisons of all-oral regimens, evidence (based on our analysis of published an unpublished data from a single study) indicated no significant difference in patients age 65 and over (RR, 1.11; 95% CI, 0.82 to 1.51), whereas the difference was significant in younger patients (RR, 1.21; 95% CI, 1.03 to 1.43). However, findings presented in the published paper, based on multiple logistic regression analyses, indicated that the three-drug regimen was superior to the two-drug regimen when age > 55 was taken into account. Analysis of patients over age 65 and taking drug regimen into account was not presented. The strength of this evidence to answer the question posed here was low.

For comparisons of mixed oral and intravenous regimens, four randomized controlled trials (RCTs) reported subgroup analyses based on age and we found the strength of this evidence to be moderate. When compared to a two-drug regimen where the 5-HT3 antagonist is administered on day one only, a mixed oral and injectable three-drug regimen containing aprepitant was superior in rates of complete response across the five-day period from start of chemotherapy (RR, 1.39; 95% CI, 1.17 to 1.64). These findings were limited in that they only related to this specific comparison and to only one outcome measure, did not include evidence on comparative harms, and some of the data were unpublished. Based on a single trial, comparison of a mixed oral and injectable three-drug regimen containing aprepitant with a two-drug regimen that continued administration of the 5-HT3 antagonists beyond day one found no statistically significant difference between regimens in complete response over the entire treatment period (RR, 1.13; 95% CI, 0.94 to 1.38), while the analysis of data for younger patients indicated a statistically significant benefit for the three-drug regimen (RR, 1.22; 95% CI, 1.03 to 1.45).

Future research is needed to clarify the benefits of three-drug regimens compared with various two-drug regimens in patients over age 65. Trials enrolling older patients, assessing more outcomes (for example patient-relevant outcomes such as total control and ability to tolerate sequential chemotherapy), and clearly assessing potential differences in adverse effects are needed.

#### Is there evidence of disparate effects on age, gender, socioeconomic status, or ethnicity/race?

The evidence base had strong applicability to women, with approximately 60% of all enrolled patients across the studies being female. While women experience higher rates of chemotherapy-induced nausea and vomiting than men, it appeared that both oral and mixed oral and injectable three-drug regimens were superior to two-drug regimens in women, with women achieving a slightly higher rate of complete response compared with men. In pooled analysis of data from two RCTs comparing a mixed oral and injectable three-drug regimen containing aprepitant with a two-drug regimen not containing aprepitant, 42% (435/1043) of the patients were women and the rate of complete response across both treatments was higher among men (61%) than women (53%). In comparison to the two-drug regimen, the aprepitant-containing regimen resulted in a difference of 25% in complete response over five days in women (our calculation of unadjusted relative risk, 1.65; 95% CI, 1.37 to 2.00) while the difference among men was 16% (our calculation of unadjusted relative risk, 1.30; 95% CI, 1.14 to 1.48). The strength of this evidence was moderate, largely because of the risk of bias resulting from a pooled analysis including data from two of eleven possible RCTs making comparisons of mixed oral and intravenous regimens, no regimens given by the same route, and no evidence on comparative harms. Further research may change our confidence in the estimate of effect and may change the estimate. However, there was inadequate evidence on any differences in harms to make conclusions.

Insufficient evidence was available for evaluating disparate effects on socioeconomic status or ethnicity/race.

#### Are certain groups more likely to receive one treatment over another, due to prescription trends in a geographic region, socioeconomic status, health insurance coverage, etc.?

No evidence on prescription trends based on geographic region, socioeconomic status, or health insurance coverage was found. The only relevant studies we found provided low-strength evidence that, among patients receiving primarily moderate to highly emetogenic single-day chemotherapy regimens, the choice of antiemetic regimen was not associated significantly with the patient’s prior experience with chemotherapy-induced nausea and vomiting or the patient’s age, sex, alcohol use, or baseline Eastern Cooperative Oncology Group performance status.

## Conclusions

For the maximal patient outcome of total control (no emesis, no use of rescue medication, no or only mild nausea), the evidence was strongest in support of a significant increase with mixed oral and injectable three-drug regimens containing aprepitant compared with two-drug regimens without aprepitant during the overall study period, as well as during both the acute and delayed treatment periods in adults undergoing highly emetogenic chemotherapy. However, the benefit of a multi-day, three-drug, aprepitant-containing regimen was minimal during the acute period and only became larger in magnitude during the overall and delayed periods when the control group was administered the 5-HT3 antagonist on day one only. For all-oral regimens, comparisons of regimens with or without aprepitant, or comparisons between two-drug regimens without aprepitant, there was low-strength evidence of no significant differences for the outcome of total control. No conclusions could be reached about total control for the comparison among different mixed two-drug regimens, without aprepitant, as evidence was unavailable for this outcome.

For complete response (no emesis, no use of rescue medication), there was predominantly high-strength evidence indicating a significant increase in benefit with three-drug regimens containing aprepitant compared with two-drug regimens without aprepitant during all study periods, regardless of whether the antiemetics were all given by an oral route or mixed oral and intravenous routes. Again, however, in the case where mixed routes were used in patients undergoing primarily highly emetogenic chemotherapy, the benefit of a multi-day, three-drug, aprepitant-containing regimen was minimal during the acute period and only became larger in magnitude during the overall and delayed periods when the control group was administered the 5-HT3 antagonist on day one only. There was only low-strength evidence of no significant differences in complete response between different mixed oral and intravenous route two-drug regimens, without aprepitant. No conclusions could be reached about complete response for the comparison among different all-oral, two-drug regimens, without aprepitant, as evidence was unavailable for this outcome.

Overall, comparative evidence on the impact of antiemetic regimens on the patient’s ability to tolerate subsequent chemotherapy sessions was low strength. Based on a single study of Chinese women undergoing moderately emetogenic chemotherapy, an all-oral, three-drug, aprepitant-containing regimen resulted in significantly fewer patients needing to delay subsequent chemotherapy sessions compared with an all-oral two-drug regimen not containing aprepitant. Applicability of these findings to a broader population was not clear. For mixed oral and intravenous regimens, no difference in the rate of completion of six cycles of chemotherapy was found between three-drug aprepitant-containing regimens and two-drug regimens, based on a pooled analysis of data from extensions phases of two short-term trials. Further studies designed with this primary outcome are needed to reliably answer this question.

There were no significant differences found between any regimens in incidence of overall adverse events for three-drug, aprepitant-containing regimens compared with two-drug regimens without aprepitant both when all-oral regimens were compared in patients undergoing moderately emetogenic chemotherapy (moderate-strength evidence) and when mixed oral and intravenous regimens were compared in patients undergoing highly emetogenic chemotherapy (high-strength evidence). There was only low-strength evidence of no significant differences in incidence of overall adverse events between different two-drug regimens without aprepitant, regardless of whether they were all given orally or using a mixed oral and intravenous regimen.

The applicability of this evidence to patients age 65 and older was still somewhat limited, with only four studies reporting subgroup analyses. When compared to a two-drug regimen where the 5-HT3 antagonist was administered on day one only, a mixed oral and intravenous three-drug regimen containing aprepitant was superior in rates of complete response across the five-day period from start of chemotherapy. These findings were limited in that they only related to this specific comparison and to only one outcome measure, did not include evidence on comparative harms, and some of the data are unpublished. The evidence base had strong applicability to women, with approximately 60% of all enrolled patients across the studies being female. While women experienced higher rates of chemotherapy-induced nausea and vomiting than men, it appeared that both oral and mixed intravenous/oral three-drug regimens were superior to two-drug regimens in women, with women achieving a slightly higher rate of complete response compared to men. However, there was inadequate evidence on any differences in harms to make conclusions.

Insufficient evidence was available for evaluating disparate effects on socioeconomic status or ethnicity/race. Although we attempted to identify studies in patients undergoing radiation, only one study was available and it was rated poor quality.