# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Ethan M. Basch, MD
  Associate Professor
  American Society of Clinical Oncology and The Memorial Sloan-Kettering Cancer Center
  New York, NY
- Paul Hesketh, MD
  Director, Thoracic Oncology
  Lahey Clinic Medical Center
  Burlington, MA
- Gary H. Lyman, MD, MPH, FRCP (Edin)
  Professor of Medicine and Director
  American Society of Clinical Oncology and Duke University School of Medicine and Cancer Center
  Durham, NC
- Henry Nicholson, MD, MPH
  Professor and Chair, Department of Pediatrics
  Oregon Health & Science University
  Portland, OR
- Ann Alexis Prestrud, M.P.H.
  Guideline Specialist
  American Society of Clinical Oncology
  Alexandria, VA