# EVIDENCE TABLES

Evidence Table 1 Chemotherapy: Placebo-controlled trials

Evidence Table 2 Quality assessments of the chemotherapy placebo-controlled trials

Evidence Table 3 Chemotherapy: Head-to-head trials

Evidence Table 4 Quality assessments of chemotherapy head-to-head trials

Evidence Table 5 Long-term uncontrolled intervention studies of safety and adverse events

Evidence Table 6 Quality assessment of long-term uncontrolled intervention studies of safety and adverse events

Abbreviation: Term
BEAM: Carmustine, etoposide, cytosine, arabinoside, melphalan
BU/CY: Busulfan
ICE: Ifosfamide, carboplatin, VP-16
MMT: Malignant Mesenchymal Tumor
ACSO: American Society of Clinical Oncology
AEs: Adverse Events
Apr: Aprepitant
BCNU/VP/CY: Carmustine
bid: Twice daily
BMT: Bone marrow transplant
CA: Cancer
Chemo: Chemotherapy
CHOP: Cyclophosphamide, hydroxydaunomycin, Oncovin, and prednisone
CINV: Chemotherapy-Induced Nausea and Vomiting
CMV: Cisplatin, methotrexate, vinblastine
CP: Complete protection
CR: Complete Response
CT: Controlled trial
CY: Cyclophosphamide
DB: Double-blind
Dex: Dexamethasone
ECOG: Eastern Cooperative Oncology Group
EP: Etoposide and cisplatin
FAC: 5-fluorouracil, doxorubicin and cyclophosphamide
FEC: Fluorouracil, epirubicin, cyclophosphamide
FEP: Fluorouracil (bolus), epirubicin, cisplatin
FLIE: Functional Living Index-Emesis questionnaire
FU: Follow-up
GRADEX: Granisetron+dexamethasone
Hrs: Hours
IV: Intravenous
Mg: Milligrams
mm: Millimeter
MR: Major Response
MTZ: Mitoxantrone
N/A: Not applicable
N/V: Nausea/vomiting
NCI: National Cancer Institute
NR: Not reported
NS: Not specified
Ond: Ondansetron
ONDEX: Ondansetron+dexamethasone
PO: Palonosetron
Pts: patients
QD: Daily
RCT: Randomized controlled trial
TANC: Paclitaxel and carboplatin
TBI: Total body irradiation based
TC: Total control
TMI: Total marrow irradiation
TRODEX: Tropisetron+dexamethasone
ULN: Upper limit of normal
VAS: Visual analog score
VP: Etoposide
wk: Week
yr: Year