# Data submitted by Merck Inc. through public comment process

The text states that P values were not provided for some quality of life outcomes. We apologize for the omission, and present them below. Please add these P values to the discussion of quality of life for these studies. In the study by Hesketh et al (Reference 33) the numbers of patients reporting no significant impact of chemotherapy-induced nausea and vomiting on quality of life was 188 out of 254 (74.0%) in the aprepitant-treated group, compared to 162/252 (64.3%) in the standard care group. The difference between groups was statistically significant (P<0.05). In the study by Poli-Bigelli et al (Reference 35) the numbers of patients reporting no significant impact of chemotherapy-induced nausea and vomiting on quality of life was 189 out of 253 (74.7%) in the aprepitant-treated group, compared to 162/255 (63.5%) in the standard care group. The difference between groups was statistically significant (P<0.01).

The question of whether the results of this review can be applied patients over the age of 65 is of special interest to the agency contracting for this technology assessment. For this reason it is important that all available evidence be considered when addressing the issue. The EPC has not considered evidence that had previously been made available to it during the DERP review process. Further, it has not considered the results of a good quality review assessing subgroup data in two previously published trials. This review, by Hesketh et al. (Supportive Care in Cancer; published first online September 2009) assesses subgroup analyses conducted as part of two trials discussed in the current AHRQ review. The trials are Hesketh et al., 2003 (Reference 33) and Poli-Bigelli et al., 2003 (Reference 35).

- The review found that younger age is associated with a greater risk of chemotherapy-induced nausea and vomiting, but that aprepitant reduces risk of this outcome to the same extent among patients younger than age 65 and among those older than age 65. That is, aprepitant reduced the risk of chemotherapy-induced nausea and vomiting regardless of the presence or absence of risk factors for this outcome. We urge the EPC to examine this review and incorporate its findings into the final version of its document.
- Examination of data from the same two studies (Hesketh et al., 2003 and Poli-Bigelli et al., 2003) led the US FDA to conclude that “No overall differences in safety or effectiveness were observed between these subjects [Those over the ages of 65 or 75] and younger subjects.” This observation has been incorporated into the FDA-approved product label.
- The subgroup analyses supporting this wording in the product label were conducted a priori as part of the planned protocols of the two studies. The results of these analyses were not published for reasons of space, but were shared with the EPC as part of their DERP review. We present them once again here and urgently request that the EPC incorporate them into their review.
- 13 were age 75 or over, 9 (69.2%) of these had a complete response to antiemetic therapy
- 247 were under age 75, 127 (51.4%) of these had a complete response to antiemetic therapy “Complete response” was defined as no emesis and no need for rescue therapy. Multiple regression analysis conducted as part of the a priori study protocol found no effect of age on response rate (P value not recorded).

In the study published by Hesketh et al., (2003; Reference 33), patients ranged in age from 18 to 84. Patients were randomized to an aprepitant regimen including aprepitant, ondansetron and dexamethasone, or a control regimen including ondansetron and dexamethasone. There were 520 patients with evaluable data in the intent to treat population. Of these, there were 182 patients aged 65 or over, and 30 aged 75 or over.

■ In the Aprepitant group, there were 260 patients, of whom:
  - 98 were age 65 or over, 79 (80.6%) of these had a complete response to antiemetic therapy.
  - 162 were under age 65, 110 (67.9%) of these had a complete response to antiemetic therapy.
  - 17 were age 75 or over, 16 (94.1%) of these had a complete response to antiemetic therapy.
  - 243 were under age 75, 173 (71.2%) of these had a complete response to antiemetic therapy.
■ In the Control group, there were 260 patients, of whom:
  - 84 were age 65 or over, 50 (59.5%) of these had a complete response to antiemetic therapy.
  - 176 were under age 65, 86 (48.9%) of these had a complete response to antiemetic therapy

In the study published by Poli-Bigelli et al., (2003; Reference 35), patients ranged in age from 18 to 82. Patients were randomized to an aprepitant regimen including aprepitant, ondansetron and dexamethasone, or a control regimen including ondansetron and dexamethasone. There were 523 patients with evaluable data in the intent to treat population. Of these, there were 129 patients aged 65 or over, and 21 aged 75 or over.

■ In the Aprepitant group, there were 260 patients, of whom:
  - 65 were age 65 or over, 45 (69.2%) of these had a complete response to antiemetic therapy.
  - 195 were under age 65, 118 (60.5%) of these had a complete response to antiemetic therapy.
  - 11 were age 75 or over, 9 (81.8%) of these had a complete response to antiemetic therapy.
  - 249 were under age 75, 154 (61.8%) of these had a complete response to antiemetic therapy.
■ In the Control group, there were 263 patients, of whom:
  - 64 were age 65 or over, 30 (46.9%) of these had a complete response to antiemetic therapy.
  - 199 were under age 65, 84 (42.2%) of these had a complete response to antiemetic therapy.
  - 10 were age 75 or over, 5 (50.0%) of these had a complete response to antiemetic therapy.
  - 253 were under age 75, 109 (43.1%) of these had a complete response to antiemetic therapy.

“Complete response” was defined as no emesis and no need for rescue therapy. Multiple regression analysis conducted as part of the a priori study protocol found no effect of age on response rate (p value not recorded).

In addition to the two studies on which the FDA and Hesketh (2009) based their conclusions, at least two other clinical trials meeting EPC inclusion criteria included a priori analyses of the effect of age on complete response, the results of which were not published. We present them here, and request that the EPC include them in their final analysis.

- In the study by Warr et al., 2005 (Reference 27), patients were randomized to an aprepitant regimen including aprepitant, ondansetron and dexamethasone, or a control regimen including ondansetron and dexamethasone. Patient ages ranged from 23 to 78 years. There were 857 patients with evaluable data in the intent to treat population. Of these, there were 129 patients aged 65 or over, and 19 aged 75 or over.
  ○ In the Aprepitant group, there were 433 patients, of whom:
    ■ 69 were age 65 or over, 42 (60.9%) of these had a complete response to antiemetic therapy.
    ■ 364 were under age 65, 178 (48.9%) of these had a complete response to antiemetic therapy.
    ■ 12 were age 75 or over, 9 (75.0%) of these had a complete response to antiemetic therapy.
    ■ 421 were under age 75, 211 (50.1%) of these had a complete response to antiemetic therapy.
  ○ In the Control group, there were 424 patients, of whom:
    ■ 60 were age 65 or over 33 (55.0%) of these had a complete response to antiemetic therapy.
    ■ 364 were under age 65, 147 (40.4%) of these had a complete response to antiemetic therapy.
    ■ 7 were age 75 or over, 4 (57.1%) of these had a complete response to antiemetic therapy
    ■ 417 were under age 75, 176 (42.2%) of these had a complete response to antiemetic therapy.
    ■ “Complete response” was defined as no emesis and no need for rescue therapy. Multiple regression analysis conducted as part of the a priori study protocol found no effect of age on response rate between patients aged 65 and over and patients who were less than 65 years old (p=0.788) or between patients aged 75 and over and patients who were less than 75 years old (p=0.631).
    ■ In the study published by Schmoll et al., (2006; Reference 36), patients were randomized to an aprepitant regimen including aprepitant, ondansetron and dexamethasone, or a control regimen including ondansetron and dexamethasone. Patients raged in age from 20 to 82. There were 484 patients with evaluable data in the intent to treat population. Of these, there were 156 patients aged 65 or over, and 15 aged 75 or over.
- In the Aprepitant group, there were 243 patients, of whom:
  ○ 80 were age 65 or over 63 (78.8%) of these had a complete response to antiemetic therapy.
  ○ 163 were under age 65, 112 (68.7%) of these had a complete response to antiemetic therapy.
  ○ 9 were age 75 or over 7 (77.8%) of these had a complete response to antiemetic therapy.
  ○ 234 were under age 75, 168 (71.8%) of these had a complete response to antiemetic therapy.
- In the Control group, there were 241 patients, of whom:
  ○ 76 were age 65 or over, 53 (69.7%) of these had a complete response to antiemetic therapy.
  ○ 165 were under age 65, 93 (56.4%) of these had a complete response to antiemetic therapy.
  ○ 6 were age 75 or over, 3 (50.0%) of these had a complete response to antiemetic therapy.
  ○ 235 were under age 75, 143 (60.9%) of these had a complete response to antiemetic therapy.

“Complete response” was defined as no emesis and no need for rescue therapy. Multiple regression analysis conducted as part of the a priori study protocol found no effect of age on response rate between patients aged 65 and over and patients who were less than 65 years old (P=0.919) or between patients aged 75 and over and patients who were less than 75 years old (P=0.612).