# Strength of evidence

Table 1 Key Question 1a: Comparative benefits for all-oral regimens with and without aprepitant

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% Confidence Interval) | Low, Moderate, High
Total Control: Overall
1; 124 | Moderate (RCT, fair) | N/A | Direct | Imprecise | 0.84 (0.48, 1.47) | Low
Total Control: Acute
1; 124 | Moderate (RCT, fair) | N/A | Direct | Imprecise | 0.94 (0.68, 1.30) | Low
Total Control: Delayed
1; 124 | Moderate (RCT, fair) | N/A | Direct | Imprecise | 0.82 (0.57, 1.17) | Low
Complete Response: Overall
3; 1769 | Moderate (RCT, fair) | Consistent | Direct | Precise | 1.22 (1.12, 1.33)^a^ | High
Complete Response: Acute
3; 1767 | Moderate (RCT, fair) | Inconsistent | Direct | Precise | 1.11 (1.06, 1.16)^a^ | Moderate
Complete Response: Delayed
3; 1769 | Moderate (RCTs, fair) | Consistent | Direct | Precise | 1.15 (1.06, 1.24) a | High
Delay in Subsequent Chemotherapy
1, 124 | Moderate (RCT; fair) | N/A | Direct | Precise | 0.29 (0.12, 0.71) | Moderate

a Does not included data from Yeo 2009, due to overlap of 44 patients from Warr 2005. In Yeo 2009, the differences between aprepitant-based and standard antiemetic regimens in acute and delayed complete response rates were not statistically significant.

Table 2 Key Question 1a: Comparative benefits for all-oral, two-drug regimens of a 5-HT3 antagonist and dexamethasone

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% CI) | Low, Moderate, High
Total Control: Acute
1; 61 | Moderate (RCT; Fair Quality) | N/A | Direct | Imprecise | 1.02 (0.58, 1.76) | Low
Total Control: Delayed
Not reported
Complete Response: Acute
Not reported
Complete Response: Delayed
Not reported
Ability to tolerate sequential chemotherapy sessions
Not reported

Table 3 Key Question 1c: Comparative benefits of mixed oral and injectable regimens, with and without aprepitant

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% Confidence Interval) | Low, Moderate, High
Total Control: Overall
3; 1300 | Moderate (RCTs, all fair) | Consistent | Direct | Precise | 1.30 (1.10, 1.54) | High
Total Control: Acute
3; 1301 | Moderate (RCTs, all fair) | Consistent | Direct | Precise | 1.12 (1.03, 1.21) | High
Total Control: Delayed
3; 1301 | Moderate (RCTs, all fair) | Consistent | Direct | Precise | 1.36 (1.11, 1.67) | High
Complete Response: Overall
3; 1300 | Moderate (RCTs; all fair) | Consistent | Direct | Precise | 1.45 (1.32, 1.60)^a^ | High
Complete Response: Acute
5; 2175 | Moderate (RCTs; all fair) | Consistent | Direct | Precise | 1.15 (1.10, 1.21) | High
Complete Response: Delayed
3; 1299 | Moderate (RCTs; all fair) | Consistent | Direct | Precise | 1.43 (1.31, 1.56)^a^ | High
Ability to tolerate sequential chemotherapy sessions
Not reported

a Data were pooled from 3 trials with similar control-group regimens on days 2 through 4–5 (i.e., monotherapy with oral dexamethasone 8 mg bid or qd). Meta-analyses did not include data from another trial (Schmoll 2006), in which the control group regimen consisted of oral ondansetron 8 mg plus dexamethasone 8 mg, both BID, on days 2 through 4. In Schmoll 2006, the magnitudes of effect were smaller, but still significant, in the overall study period (RR 1.19, 95% CI 1.05 to 1.35) and delayed period (RR, 1.17; 95% CI, 1.04 to 1.33).

Table 4 Key Question 1c: Comparative benefits of mixed oral and injectable regimens containing a 5-HT3 antagonist plus dexamethasone

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% CI) | Low, Moderate, High
Total Control: Acute
Not reported
Total Control: Delayed
Not reported
Complete Response: Overall
1; 102 | Moderate (RCT; Fair quality | N/A | Indirect | Imprecise | 0.97 (0.88, 1.07) | Low
Complete Response: Acute
1; 102 | Moderate (RCT; Fair quality | N/A | Indirect | Imprecise | 0.97 (0.88, 1.07) | Low
Complete Response: Delayed
1; 102 | Moderate (RCT; Fair quality | N/A | Indirect | Imprecise | 1.00 (0.60, 1.66) | Low
Ability to tolerate sequential chemotherapy sessions
Not reported

Table 5 Key Question 2a: Comparative harms for all-oral regimens with and without aprepitant

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% Confidence Interval) | Low, Moderate, High
Overall Adverse Events
1, 848 | Moderate (RCT; fair) | N/A | Direct | Precise | 0.93 (0.85, 1.03) | Moderate

Table 6 Key Question 2a: Comparative harms for all-oral, two-drug regimens of a 5-HT3 antagonist and dexamethasone

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% CI) | Low, Moderate, High
Overall Adverse Events
1; 61 | Moderate (RCT; Fair Quality) | N/A | Direct | Imprecise | 1.40 (0.9, 2.21) | Low

Table 7 Key Question 2c: Comparative harms of mixed oral and injectable regimens, with and without aprepitant

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% Confidence Interval) | Low, Moderate, High
Overall Adverse Events
4; 1640 | Moderate (RCTs, all fair) | Consistent | Direct | Precise | 1.03 (0.97, 1.10) | High

Table 8 Key Question 2c: Comparative benefits of mixed oral and injectable regimens containing a 5-HT3 antagonist plus dexamethasone

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative Risk (95% CI) | Low, Moderate, High
Overall Adverse Events
1; 51 | Moderate (RCT, fair) | N/A | Direct | Imprecise | 0.85 (0.42, 1.68) | Low

Table 9 Key Question 3a: Comparison of mixed oral and injectable regimens, with and without aprepitant in patients age 65 and over

Outcome | Number of studies; Number of subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Relative risk (95% CI) | Strength of evidence
Complete Response: Total | 3; 467 | High (1 pooled analysis of 2 RCTs, unpublished data for 3 RCTs) | Consistent | Direct | Precise | 1.28 (1.09, 1.49) | Moderate
Overall Adverse Events | Not Reported

Table 10 Key Question 3c: Factors associated with prescription of antiemetic regimen

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Proportion of induced TOL | Low, Moderate, High
5 3050 | Medium to low Cohort 3 Fair quality, 2 poor quality | Consistent | Direct | Unable to assess | NA | Low
Applicability
Primarily relates to patients receiving moderate to highly emetogenic chemotherapy given on a single day in inpatient or outpatient setting, and including a variety of cancers with breast, colorectal, and lung cancer being the most common. Does not relate to aprepitant or palonosetron.