# APPENDICES

Appendix A US Food and Drug Administration recommendations for adult dosages

Appendix B Glossary

Appendix C Search strategies

Appendix D Methods to assess quality of studies

Appendix E Excluded studies

Appendix F Strength of evidence

Appendix G Data submitted by Merck Inc. through public comment process