# Excluded studies

Exclusion codes: 1=foreign language, 2=outcome not included, 3=intervention not included e.g. all iv versus all iv; monotherapy; dosage form or the route of the corticosteroid was variable, unclear, or both; regimen included combination of 5-HT3 with another non corticosteroid drug, 4=population not included, 5=publication type not included, 6=study design not included.

Excluded studies | Exclusion code
Head-to-head trials
Adamo V, Aiello R, Altavilla G, et al. Ondansetron (OND) vs granisetron (GRA) in the control of chemotherapy-induced acute emesis. European Journal of Cancer. 1995;31Ÿ(Suppl 5):S256 Abs. 1225. | 5
Aapro M, Bertoli L, Lordick F, Bogdanova N, Macciocchi A. Palonosetron (PALO) is effective in preventing acute and delayed chemotherapy-induced-nausea and vomiting (CINV) in patients receiving highly emetogenic chemotherapy (HEC). [abstract]. Support Care Cancer. 2003;11(Suppl):391. | 6
Aapro MS, Grunberg SM, Manikhas GM, et al. A phase III, double-blind, randomized trial of palonosetron compared with ondansetron in preventing chemotherapy-induced nausea and vomiting following highly emetogenic chemotherapy. Ann Oncol. 2006;17(9):1441–1449. | 6
Abali H, Celik I. Tropisetron, ondansetron, and granisetron for control of chemotherapy-induced emesis in Turkish cancer patients: a comparison of efficacy, side-effect profile, and cost. Cancer Invest. 2007;25(3):135–139. | 6
Abang AM, Takemoto MH, Pham T, et al. Efficacy and safety of oral granisetron versus i.v. granisetron in patients undergoing peripheral blood progenitor cell and bone marrow transplantation. Anticancer Drugs. 2000;11(2):137–142. | 3
Anonymous. Ondansetron versus granisetron, both combined with dexamethasone, in the prevention of cisplatin-induced emesis. Italian Group of Antiemetic Research. Ann Oncol. 1995;6(8):805–810. | 6
Audhuy B, Cappelaeare P, Claverie N. Double-blind, comparative trial of the anti-emetic efficacy of two IV doses of dolasetron mesilate (DM) and granisetron (G) after infusion of high-dose cisplatin chemotherapy (CT). Eur-J-Cancer. 1995;31ƒ(Suppl 5):S253 Abs.1213. | 5
Audhuy B, Cappelaere P, Claverie N. Double-blind comparison of the antiemetic efficacy of two single IV doses of dolasetron and one IV dose of granisetron after cisplatin (80 mg/m2) chemotherapy. Supportive Care in Cancer. 1995;3(338):21. | 5
Audhuy B, Cappelaere P, Martin M, et al. A double-blind, randomised comparison of the anti-emetic efficacy of two intravenous doses of dolasetron mesilate and granisetron in patients receiving high dose cisplatin chemotherapy. Eur J Cancer. 1996;32A(5):807–813. | 6
Barrajon E, De Las Penas R. Randomised double blind crossover study comparing ondansetron, granisetron and tropisetron. A cost-benefit analysis. Support Care Cancer. 2000;8(4):323–333. | 6
Beck T, Bryson J, Crawford K, McQuade B. Oral ondansetron (OND) for the prevention of nausea and vomiting (n&v) associated with cisplatin (CDDP) chemotherapy (CT). Ann-Oncol. 1998;9(Suppl 4):142. | 5
Birmingham SD, Mecklenburg BW, Lujan E, Dacanay RG, Boyle PK, Green R. Dolasetron versus ondansetron as single-agent prophylaxis for patients at increased risk for postoperative nausea and vomiting: a prospective, double-blind, randomized trial. Military Medicine. 2006;171(9):913–916. | 6
Bonneterre J, Hecquet B, Fenaux I, et al. Granisetron (IV) compared with ondansetron (IV plus oral) in the prevention of nausea and vomiting induced by moderately-emetogenic chemotherapy. A cross-over study. Bulletin du Cancer. 1995;82(12):1038–1043. | 1
Bubalo J, Seelig F, Karbowicz S, Maziarz RT. Randomized open-label trial of dolasetron for the control of nausea and vomiting associated with high-dose chemotherapy with hematopoietic stem cell transplantation. Biology of blood and marrow transplantation : journal of the American Society for Blood and Marrow Transplantation. 2001;7(8):439–445. | 6
Bubalo J, Seelig F, Karbowicz S, Maziarz RT. Randomized open-label trial of dolasetron for the control of nausea and vomiting associated with high-dose chemotherapy with hematopoietic stem cell transplantation. Biology of Blood and Marrow Transplantation. 2001;7(8):439–445. | 3
Buyukavci M, Olgun H, Ceviz N. The effects of ondansetron and granisetron on electrocardiography in children receiving chemotherapy for acute leukemia. American Journal of Clinical Oncology. Apr 2005;28(2):201–204. | 2
Candiotti KA, Nhuch F, Kamat A, et al. Granisetron versus ondansetron treatment for breakthrough postoperative nausea and vomiting after prophylactic ondansetron failure: a pilot study. Anesthesia & Analgesia. 2007;104(6):1370–1373. | 6
Cho JY, Park JO, Rha SY, Yoo NC, Kim JH, Roh JK. A comparative study of granisetron i.v. versus ondansetron i.v./oral in the prevention of nausea and vomiting associated with moderately emetogenic chemotherapy. Ann-Oncol. 1996;7(Suppl 5):142. | 5
Cocquyt V, Van Belle S, Reinhardt RR, et al. Comparison of L-758,298, a prodrug for the selective neurokinin-1 antagonist, L-754,030, with ondansetron for the prevention of cisplatin-induced emesis. Eur J Cancer. 2001;37(7):835–842. | 6
Corapcioglu F, Sarper N. A prospective randomized trial of the antiemetic efficacy and cost-effectiveness of intravenous and orally disintegrating tablet of ondansetron in children with cancer. Pediatr Hematol Oncol. Mar 2005;22(2):103–114. | 6
de Wit R, de Boer AC, vd Linden GH, Stoter G, Sparreboom A, Verweij J. Effective cross-over to granisetron after failure to ondansetron, a randomized double blind study in patients failing ondansetron plus dexamethasone during the first 24 hours following highly emetogenic chemotherapy. Br J Cancer. 2001;85(8):1099–1101. | 6
Del Favero A, Bergerat J, Chemaissani A, Dressler H. Single oral doses of dolasetron versus multiple doses of ondansetron in preventing emesis after moderately emetogenic chemotherapy. Supportive Care in Cancer. 1995A;3(337):19. | 5
Del Favero A, Roila F, Tonato M, et al. Ondansetron versus granisetron, both combined with dexamethasone, in the prevention of cisplatin-induced emesis. Ann Oncol. 1995;6(8):805–810. | 6
Diemunsch P, Gan TJ, Philip BK, et al. Single-dose aprepitant vs ondansetron for the prevention of postoperative nausea and vomiting: a randomized, double-blind phase III trial in patients undergoing open abdominal surgery. British Journal of Anaesthesia. 2007;99(2):202–211. | 6
Eisenberg P, Figueroa-Vadillo J, Zamora R, et al. Improved Prevention of Moderately Emetogenic Chemotherapy-Induced Nausea and Vomiting with Palonosetron, a Pharmacologically Novel 5-HT3 Receptor Antagonist: Results of a Phase III, Single-Dose Trial Versus Dolasetron. Cancer. 2003;98(11):2473–2482. | 6
Fabi A, Ciccarese M, Metro G, et al. Oral ondansetron is highly active as rescue antiemetic treatment for moderately emetogenic chemotherapy: results of a randomized phase II study. Support Care Cancer. Dec 2008;16(12):1375–1380. | 3
Fauser AA, Bergerat Cocquyt V, Chemaissani A, Del Favero A, Dressler HT. Double-blind, comparison trial of four single oral doses of dolasetron mesilate (DM) and multiple doses of ondansetron (OND) for emesis prevention after moderately emetogenic chemotherapy (CT). Eur-J-Cancer. 1995;31ƒ(Suppl 5):S254 Abs. 1217. | 5
Fauser AA, Duclos B, Chemaissani A, et al. Therapeutic equivalence of single oral doses of dolasetron mesilate and multiple doses of ondansetron for the prevention of emesis after moderately emetogenic chemotherapy. European Journal of Cancer Part A. 1996;32(9):1523–1529. | 3
Forni C, Ferrari S, Loro L, et al. Granisetron, tropisetron, and ondansetron in the prevention of acute emesis induced by a combination of cisplatin-Adriamycin and by high-dose ifosfamide delivered in multiple-day continuous infusions. Support Care Cancer. 2000;8(2):131–133. | 6
Fumoleau P, Giovannini M, Rolland F, Votan B, Paillarse JM. Ondansetron suppository: An effective treatment for the prevention of emetic disorders induced by cisplatin-based chemotheraphy. Oral Oncology. 1997;33(5):354–358. | 6
Gan TJ, Apfel CC, Kovac A, et al. A randomized, double-blind comparison of the NK1 antagonist, aprepitant, versus ondansetron for the prevention of postoperative nausea and vomiting. Anesthesia & Analgesia. 2007;104(5):1082–1089. | 6
Gebbia V, Cannata G, Testa A, et al. Ondansetron versus granisetron in the prevention of chemotherapy-induced nausea and vomiting: Results of a prospective randomized trial. Cancer. 1994;74(7):1945–1952. | 3
Gralla R, Lichinitser M, Van der Vegt S, et al. Palonosetron improves prevention of chemotherapy-induced nausea and vomiting following moderately emetogenic chemotherapy: Results of a double-blind randomized phase III trial comparing single doses of palonosetron with ondansetron. Ann Oncol. 2003;14(10):1570–1577. | 6
Gralla RJ, Navari RM, Hesketh PJ, et al. Single-dose oral granisetron has equivalent antiemetic efficacy to intravenous ondansetron for highly emetogenic cisplatin-based chemotherapy. J Clin Oncol. 1998;16(4):1568–1573. | 3
Hesketh P, Navari R, Grote T, et al. Double-blind, randomized comparison of the antiemetic efficacy of intravenous dolasetron mesylate and intravenous ondansetron in the prevention of acute cisplatin-induced emesis in patients with cancer. J Clin Oncol. 1996;14(8):2242–2249. | 6
Jaing T-H, Tsay P-K, Hung I-J, Yang C-P, Hu W-Y. Single-dose oral granisetron versus multidose intravenous ondansetron for moderately emetogenic cyclophosphamide-based chemotherapy in pediatric outpatients with acute lymphoblastic lukemia. Pediatr Hematol Oncol. 2004;21(3):227–235. | 6
Jantunen IT, Muhonen TT, Kataja VV, Flander MK, Teerenhovi L. 5-HT3 receptor antagonists in the prophylaxis of acute vomiting induced by moderately emetogenic chemotherapy--a randomised study. Eur J Cancer. 1993;29A(12):1669–1672. | 6
Kalaycio M, Mendez Z, Pohlman B, et al. Continuous-infusion granisetron compared to ondansetron for the prevention of nausea and vomiting after high-dose chemotherapy. J Cancer Res Clin Oncol. 1998;124(5):265–269. | 6
Lacerda JF, Martins C, Carmo JA, et al. Randomized trial of ondansetron, granisetron, and tropisetron in the prevention of acute nausea and vomiting. Transplantation Proceedings. 2000;32(8):2680–2681. | 5
Leonardi V, Iannitto E, Meli M, Palmeri S. Ondansetron (OND) vs granisetron (GRA) in the control of chemotherapy induced acute emesis: A multicentric randomized trial. Oncol Rep. 1996;3(5):919–923. | 6
Lofters WS, Pater JL, Zee B, et al. Phase III double-blind comparison of dolasetron mesylate and ondansetron and an evaluation of the additive role of dexamethasone in the prevention of acute and delayed nausea and vomiting due to moderately emetogenic chemotherapy. J Clin Oncol. 1997;15(8):2966–2973. | 6
Lofters WS, Zee B. Dolasetron (DOL) vs ondansetron (OND) with and without dexamethasone (DEX) in the prevention of nausea (N) and vomiting (V) in patients (pts) receiving moderately emetogenic chemotherapy (MEC). Eur-J-Cancer. 1995A;31?(Suppl 5):S252 Abs. 1205. | 5
Lofters WS, Zee B. Dolasetron (DOL) vs ondansetron (OND) with and without dexamethasone (DEX) in the prevention of nausea (N) and vomiting (V) in patients (PTS) receiving moderately emetogenic chemotherapy (MEC). The Symptom Control Commitee of the National Cancer Institute of Canada Clinical Trials Group and Nordic Merrel Dow Research Canada. Supportive Care in Cancer. 1995;3(338). | 5
Mabro M, Kerbrat P. Comparative trial of oral granisetron and intravenous ondansetron in patients receiving chemotherapy for breast cancer. Bulletin du Cancer. 1999;86(3):295–301. | 1
Mantovani G, Maccio A, Bianchi A, et al. Comparison of granisetron vs ondansetron vs tropisetron in the prophylaxis of acute nausea and vomiting induced by highly emetogenic chemotherapy (high-dose cisplatin) for treatment of primary head and neck cancer: an open cross-over randomized controlled trial. Eur-J-Cancer. 1995;31?(Suppl 5):S252 Abs. 1206. | 5
Mantovani G, Maccio A, Bianchi A, et al. Comparison of granisetron, ondansetron, and tropisetron in the prophylaxis of acute nausea and vomiting induced by cisplatin for the treatment of head and neck cancer: A randomized controlled trial. Cancer. 1996;77(5):941–948. | 6
Martoni A, Angelelli B, Guaraldi M, Strocchi E, Pannuti F. An open randomised cross-over study on granisetron versus ondansetron in the prevention of acute emesis induced by moderate dose cisplatin-containing regimens. Eur J Cancer. 1996;32A(1):82–85. | 3
Massidda B, Ionta MT. Prevention of delayed emesis by a single intravenous bolus dose of 5-HT3-receptor-antagonist in moderately emetogenic chemotherapy. J Chemother. 1996;8(3):237–242. | 6
Muller D, Armbruster W, Unkel W, Apfel CC, Bornfeld N, Peters J. Blockade nozizeptiver ocularer Afferenzen durch Retrobulbaranasthesie vermindert nicht Ubelkeit und Erbrechen nach Propofol-Remifentanil-Anasthesie. [Blocking nociceptive afferents by retrobulbar bupivacaine does not decrease nausea and vomiting after propofol-remifentanil anaesthesia]. Anasthesiol-Intensivmed-Notfallmed-Schmerzther. 2003;Anasthesiologie,-Intensivmedizin,-Notfallmedizin,-Schmerztherapie-AINS. 38(11):689–694. | 1
Navari R, Gandara D, Hesketh P, et al. Comparative clinical trial of granisetron and ondansetron in the prophylaxis of cisplatin-induced emesis. J Clin Oncol. 1995;13(5):1242–1248. | 6
Noble A, Bremer K, Goedhals L, Cupissol D, Dilly SG. A double-blind, randomised, crossover comparison of granisetron and ondansetron in 5-day fractionated chemotherapy: assessment of efficacy, safety and patient preference. The Granisetron Study Group. Eur J Cancer. 1994;30A(8):1083–1088. | 6
Oge A, Alkis N, Oge O, Kartum A. Comparison of granisetron, ondansetron and tropisetron for control of vomiting and nausea induced by cisplatin. J Chemother. 2000;12(1):105–108. | 6
Orchard PJ, Rogosheske J, Burns L, et al. A prospective randomized trial of the anti-emetic efficacy of ondansetron and granisetron during bone marrow transplantation. Biol Blood Marrow Transplant. 1999;5(6):386–393. | 6
Park JO, Rha SY, Yoo NC, et al. A comparative study of intravenous granisetron versus intravenous and oral ondansetron in the prevention of nausea and vomiting associated with moderately emetogenic chemotherapy. Am J Clin Oncol. 1997;20(6):569–572. | 3
Pater JL, Lofters WS, Zee B, et al. The role of the 5-HT3 antagonists ondansetron and dolasetron in the control of delayed onset nausea and vomiting in patients receiving moderately emetogenic chemotherapy. Ann Oncol. 1997;8(2):181–185. | 6
Pectasides D, Dafni U, Aravantinos G, et al. A randomized trial to compare the efficacy and safety of antiemetic treatment with ondansetron and ondansetron zydis in patients with breast cancer treated with high-dose epirubicin. Anticancer Res. 2007;27(6C):4411–4418. | 3
Perez EA, Hesketh P, Sandbach J, et al. Comparison of single-dose oral granisetron versus intravenous ondansetron in the prevention of nausea and vomiting induced by moderately emetogenic chemotherapy: A multicenter, double-blind, randomized parallel study. J Clin Oncol. 1998;16(2):754–760. | 3
Perez EA, Lembersky B, Kaywin P, Kalman L, Yocom K, Friedman C. Comparable safety and antiemetic efficacy of a brief (30-second bolus) intravenous granisetron infusion and a standard (15-minute) intravenous ondansetron infusion in breast cancer patients receiving moderately emetogenic chemotherapy. Cancer J Sci Am. 1998;4(1):52–58. | 6
Poon RTP, Chow LWC. Comparison of antiemetic efficacy of granisetron and ondansetron in Oriental patients: A randomized crossover study. Br J Cancer. 1998;77(10):1683–1685. | 6
Raynov J, Raynova P, Kancheva T, Georgiev G. Antiemetic control in cancer patients treated with highly emetogenic chemotherapy. Journal of B.U.ON. 2000;5(3):287–291. | 3
Ruff P, Paska W, Goedhals L, et al. Ondansetron compared with granisetron in the prophylaxis of cisplatin-induced acute emesis: a multicentre double-blind, randomised, parallel-group study. The Ondansetron and Granisetron Emesis Study Group. [erratum appears in Oncology 1994 May–Jun;51(3):243]. Oncology. 1994;51(1):113–118. | 6
Saito M, Aogi K, Sekine I, et al. Palonosetron plus dexamethasone versus granisetron plus dexamethasone for prevention of nausea and vomiting during chemotherapy: a double-blind, double-dummy, randomised, comparative phase III trial. Lancet Oncology. Feb 2009;10(2):115–124. | 6
Scoponi CA, Torresi U, Di Giuseppe M, Giustozzi M. Are 5-HT3 antagonists a standard antiemetic treatment also in slightly and moderately emetogenic regimens? Oncologia. 1998;21(9):40–44. | 1
Sepulveda-Vildosola AC, Betanzos-Cabrera Y, Lastiri GG, et al. Palonosetron hydrochloride is an effective and safe option to prevent chemotherapy-induced nausea and vomiting in children. Archives of Medical Research. Aug 2008;39(6):601–606. | 6
Slaby J, Trneny M, Prochazka B, Klener P. Antiemetic efficacy of three serotonin antagonists during high-dose chemotherapy and autologous stem cell transplantation in malignant lymphoma. Neoplasma. 2000;47(5):319–322. | 6
Spector JI, Lester EP, Chevlen EM, et al. A comparison of oral ondansetron and intravenous granisetron for the prevention of nausea and emesis associated with cisplatin-based chemotherapy. Oncologist. 1998;3(6):432–438. | 3
Spina M, Valentini M, Fedele P, et al. Randomized comparison of granisetron vs ondansetron in patients (pts) with HIV-related non-Hodgkin’s lymphoma (HIV-NHL) receiving moderately emetogenic chemotherapy (CT) regimens [abstract]. Proceedings of the American Society of Clinical Oncology. 1995;14(532). | 5
Spitzer TR, Friedman CJ, Bushnell W, Frankel SR, Raschko J. Double-blind, randomized, parallel-group study on the efficacy and safety of oral granisetron and oral ondansetron in the prophylaxis of nausea and vomiting in patients receiving hyperfractionated total body irradiation. Bone Marrow Transplantation. 2000;26(2):203–210. | 6
Stewart A, McQuade B, Cronje JDE, et al. Ondansetron compared with granisetron in the prophylaxis of cyclophosphamide-induced emesis in out-patients: A multicentre, double-blind, double-dummy, randomised, parallel-group study. Oncology. 1995;52(3):202–210. | 3
Stewart L, Crawford SM, Taylor PA. The comparative effectiveness of ondansetron and granisetron in a once daily dosage in the prevention of nausea and vomiting caused by cisplatin: A double-blind clinical trial. Pharmaceutical Journal. 2000;265(7104):59–62. | 6
Sukhani R, Pappas AL, Lurie J, Hotaling AJ, Park A, Fluder E. Ondansetron and dolasetron provide equivalent postoperative vomiting control after ambulatory tonsillectomy in dexamethasone-pretreated children. Anesthesia and Analgesia. 2002;95(5):1230–1235. | 6
Tsavaris N, Kosmas C, Samarkos M, et al. Randomized comparative study of antiemetic activity of metoclopramide (M) vs ondansetron (Od) vs tropisetron vs granisetron (G) in patients receiving moderately emetogenic chemotherapy. Supportive Care in Cancer. 1996;4(252):114. | 5
Van Belle S, Lichinitser MR, Navari RM, et al. Prevention of cisplatin-induced acute and delayed emesis by the selective neurokinin-1 antagonists, L-758,298 and MK-869: A randomized controlled trial. Cancer. 2002;94(11):3032–3041. | 6
Walsh T, Morris AK, Holle LM, et al. Granisetron vs ondansetron for prevention of nausea and vomiting in hematopoietic stem cell transplant patients: Results of a prospective, double-blind, randomized trial. Bone Marrow Transplant. 2004;34(11):963–968. | 6
White L, Daly SA, McKenna CJ, et al. A comparison of oral ondansetron syrup or intravenous ondansetron loading dose regimens given in combination with dexamethasone for the prevention of nausea and emesis in pediatric and adolescent patients receiving moderately/highly emetogenic chemotherapy. Pediatr Hematol Oncol. 2000;17(6):445–455. | 6
White PF, Tang J, Hamza MA, et al. The use of oral granisetron versus intravenous ondansetron for antiemetic prophylaxis in patients undergoing laparoscopic surgery: the effect on emetic symptoms and quality of recovery. Anesthesia & Analgesia. May 2006;102(5):1387–1393. | 6
Yalcin S, Tekuzman G, Baltali E, Ozisik Y, Barista I. Serotonin receptor antagonists in prophylaxis of acute and delayed emesis induced by moderately emetogenic, single-day chemotherapy: A randomized study. American Journal of Clinical Oncology: Cancer Clinical Trials. 1999;22(1):94–96. | 6
Yonemura M, Katsumata N, Hashimoto H, et al. Randomized controlled study comparing two doses of intravenous granisetron (1 and 3 mg) for acute chemotherapy-induced nausea and vomiting in cancer patients: a non-inferiority trial. Jpn J Clin Oncol. Jul 2009;39(7):443–448. | 6
Yu Z, Liu W, Wang L, et al. The efficacy and safety of palonosetron compared with granisetron in preventing highly emetogenic chemotherapy-induced vomiting in the Chinese cancer patients: a phase II, multicenter, randomized, double-blind, parallel, comparative clinical trial. Support Care Cancer. Jan 2009;17(1):99–102. | 6
Zeidman A, Dayan DB, Zion TB, Kaufman O, Cohen AM, Mittelman M. Granisetron and ondansetron for chemotherapy-related nausea and vomiting. Haematologia (Budap). 1998;29(1):25–31. | 3
Active-control trials
On the relationship between nausea and vomiting in patients undergoing chemotherapy. Italian Group for Antiemetic Research. Support Care Cancer. May 1994;2(3):171–176.” | 2
Aapro MS, Thuerlimann B, Sessa C, de Pree C, Bernhard J, Maibach R. A randomized double-blind trial to compare the clinical efficacy of granisetron with metoclopramide, both combined with dexamethasone in the prophylaxis of chemotherapy-induced delayed emesis. Annals of Oncology. 2003;14(2):291–297. | 2
Advani SH, Gopal R, Dhar AK, Lal HM, Cooverji ND. Comparative evaluation of the clinical efficacy and safety of ondansetron and metoclopramide in the prophylaxis of emesis induced by cancer chemotherapy regimens including cisplatin. Journal of the Association of Physicians of India. 1996;44(2):127–130. | 2
Ahn MJ, Lee JS, Lee KH, Suh C, Choi SS, Kim SH. A randomized double-blind trial of ondansetron alone versus in combination with dexamethasone versus in combination with dexamethasone and lorazepam in the prevention of emesis due to cisplatin-based chemotherapy. American Journal of Clinical Oncology. 1994;17(2):150–156. | 2
Aksoylar S, Akman SA, Ozgenc F, Kansoy S. Comparison of tropisetron and granisetron in the control of nausea and vomiting in children receiving combined cancer chemotherapy. Pediatric Hematology and Oncology. 2001;18(6):397–406. | 2
Alfieri AB, Cubeddu LX. Comparative efficacy of a single oral dose of ondansetron and of buspirone against cisplatin-induced emesis in cancer patients. British Journal of Cancer. 1995;72(4):1013–1015. | 2
An TT, Liu XY, Fang J, Wu MN. Randomized trial to compare the effect of ondansetron versus metopromide plus dexamethasone in controlling delayed emesis after high-dose cisplatin. Chinese Journal of Clinical Oncology. 2002;29(8):560–562. | 2
Anonymous. Delayed emesis induced by moderately emetogenic chemotherapy: do we need to treat all patients? The Italian Group for Antiemetic Research. Annals of Oncology. 1997;8(6):561–567. | 2
Anonymous. Ondansetron versus metoclopramide, both combined with dexamethasone, in the prevention of cisplatin-induced delayed emesis. The Italian Group for Antiemetic Research. Journal of Clinical Oncology. 1997;15(1):124–130. | 2
Anonymous. Persistence of efficacy of three antiemetic regimens and prognostic factors in patients undergoing moderately emetogenic chemotherapy. Italian Group for Antiemetic Research. Journal of Clinical Oncology. 1995;13(9):2417–2426. | 2
Arechevala E, Aulitzky W, Boeckmann W, Butcher ME, Dearnaley DP, Droz JP. A randomised, double-blind comparative study of ondansetron (OND) plus dexamethasone (DEX) with metoclopramide (MCP) plus dex as anti-emetic prophylaxis during multi-day cisplatin chemotherapy. Ann-Oncol. 1992;3(Suppl 5):183. | 2
Ballatori E, Roila F, Salinaro F, et al. Ondansetron (OND) vs metoclopramide (MTC) both combined with dexamethasone (DEX) in the prevention of cisplatin (CDDP)-induced delayed emesis. The italian Group for Antiemetic Research. Supportive Care in Cancer. 1996;4(251). | 2
Basurto C, Corgna E, Picciafuoco M, et al. Cisplatin-induced delayed emesis: Pattern and prognostic factors during three subsequent cycles. Italian Group for Antiemetic Research. Annals of Oncology. 1994;5(7):585–589. | 2
Bhatia A, Tripathi KD, Sharma M. Comparison of ondansetron with metoclopramide in prevention of acute emesis associated with low dose & high dose cisplatin chemotherapy. Indian Journal of Medical Research. 2003;117(JULY):33–41. | 2
Bhatia A, Tripathi KD, Sharma M. Efficacy & tolerability of ondansetron compared to metoclopramide in dose dependent cisplatin-induced delayed emesis. Indian Journal of Medical Research. 2004;120(3):183–193. | 6
Bohn U, Aguiar J, Salinas J. Randomized cross-over trial of ondansetron (OND) and metoclopramide (MET) in the treatment of emesis induced by chemotherapy. Ann-Oncol. 1992;3(Suppl 5):187. | 2
Bohn U, Aguiar J, Salinas J. Randomized study comparing the efficacy of ondansetron and metoclopramide in the control of emesi induced by chemotherapy. Oncología. 1993;IV Congreso Nacional de la SEOM. 16(6):246. | 2
Bonneterre J, Chevallier B, Metz R, et al. A randomized double-blind comparison of ondansetron and metoclopramide in the prophylaxis of emesis induced by cyclophosphamide, fluorouracil, and doxorubucin or epirubicin chemotherapy. Journal of Clinical Oncology. 1990;8(6):1063–1069. | 2
Bonneterre J, Clavel M, the Ondansetron Breast Cancer Study G. Comparison between ondansetron (OND) tablet and alizapride (ALI) injection in the prevention of emesis induced by cytotoxic regimens in breast cancer patients. Ann-Oncol. 1992;3(Suppl 5):183. | 2
Bosi A, Guidi S, Messori A, et al. Ondansetron versus chlorpromazine for preventing emesis in bone marrow transplant recipients: A double-blind randomized study. Journal of Chemotherapy. 1993;5(3):191–196. | 2
Bosi A, Guidi S, Saccardi R, Vannucchi AM, Messori A, Rossi Ferrini P. Antiemetic prophylaxis with Ondansetron in BMT. European Journal of Cancer. 1991;27(Supp. 2):S297. | 5
Bosnjak SM, Neskovic-Konstantinovic ZB, Radulovic SS, Susnjar S, Mitrovic LB. High efficacy of a single oral dose of ondansetron 8 mg versus a metoclopramide regimen in the prevention of acute emesis induced by fluorouracil, doxorubicin and cyclophosphamide (FAC) chemotherapy for breast cancer. Journal of Chemotherapy. 2000;12(5):446–453. | 2
Bremer K, Hans K, Harjung H, Kurrle E, Uhlenbusch R. Granisetron (Gran), a selective 5- ht3-antagonist, compared to alizapride plus dexamethasone (comp) as antiemetics during five-day-cycles of cytotoxic chemotherapy. Ann-Oncol. 1990;1(Suppl):110. | 2
Bremer K, Hans K, Harjung H, Kurrle E, Uhlenbusch R. The antiemetic effectiveness of granisetron, compared with alizaprid + dexamethasone, in fractionated cytostatic therapy. Klinische Wochenschrift. 1991;69(Suppl 23):204. | 2
Bremer K, Smit P. Granisetron (G) compared to a combination of alizapride (A) plus dexamethason (D) for the prophylaxis and control of cytotoxic induce demesis over 5 days. Ann-Oncol. 1990;1(Suppl):109. | 2
Bremer K, Uhlenbusch R. 5-HT3-Receptor antagonist granisetron: antiemetic efficacy compared with alizaprid plus dexamethason during 5-day chemotherapy cycles. Onkologie. 1991;14(Suppl 3):20. | 2
Bremer K. A single-blind study of the efficacy and safety of intravenous granisetron compared with alizapride plus dexamethasone in the prophylaxis and control of emesis in patients receiving 5-day cytostatic therapy. The Granisetron Study Group. European Journal of Cancer. 1992;28A(6–7):1018–1022. | 2
Campora E, Giudici S, Merlini L, Rubagotti A, Rosso R. Ondansetron and dexamethasone versus standard combination antiemetic therapy: A randomized trial for the prevention of acute and delayed emesis induced by cyclophosphamide-doxorubicin chemotherapy and maintenance of antiemetic effect at subsequent courses. American Journal of Clinical Oncology: Cancer Clinical Trials. 1994;17(6):522–526. | 2
Campora E, Merlini L, Giudici S, Mammoliti S, Oliva C, Rosso R. Randomized trial of Ondansetron and Dexamethasone versus Metoclopramide, Dexamethasone and Orphenadrine for the control of acute and delayed FEC-FAC induced emesis. European Journal of Cancer. 1991;27(Supp. 2):S299. | 2
Campora E, Simoni C, Rosso R. Tropisetron versus ondansetron in the prevention and control of emesis in patients undergoing chemotherapy with FAC/FEC for metastatic or operated breast cancer. Minerva Med. 1994;85(1–2):25–31. | 2
Carmichael J, Bessell EM, Harris AL, et al. Comparison of granisetron alone and granisetron plus dexamethasone in the prophylaxis of cytotoxic-induced emesis.[erratum appears in Br J Cancer 1995 May;71(5):1123]. British Journal of Cancer. 1994;70(6):1161–1164. | 2
Chang C-S, Chen L-T, Huang S-M, et al. Comparison of intravenous granisetron with metoclopramide plus dexamethasone in the prevention of nausea and vomiting associated with emetogenic cytotoxic chemotherapy. Kaohsiung Journal of Medical Sciences. 1997;13(2):97–102. | 2
Chevallier B, Cappelaere P, Splinter T, et al. A double-blind, multicentre comparison of intravenous dolasetron mesilate and metoclopramide in the prevention of nausea and vomiting in cancer patients receiving high-dose cisplatin chemotherapy. Supportive Care in Cancer. 7/7/2005 1997;5(1):22–30. | 2
Chevallier B, Cappelaere P, Splinter T, Fabbro M, Claverie N. IV dolasetron (DM) vs IV metoclopramide (M) in emesis prevention after cisplatin chemotherapy (CT). Supportive Care in Cancer. 1995;3(336):16. | 2
Chevallier B, Marty M, the Ondansetron Study g. A double blind randomized study to compare the efficacy and safety of ondansetron (ND) versus ondansetron plus methylprednisolone (MPD) in combination in the prophylaxis of cisplatin induced emesis. Ann-Oncol. 1992;3(Suppl 5):182. | 2
Chevallier B. Efficacy and safety of granisetron compared with high-dose metoclopramide plus dexamethasone in patients receiving high-dose cisplatin in a single-blind study. European Journal of Cancer. 1990;26(SUPPL. 1):S33–S36. | 2
Chevallier B. The control of acute cisplatin-induced emesis - A comparative study of granisetron and a combination regimen of high-dose metoclopramide and dexamethasone. British Journal of Cancer. 1993;68(1):176–180. | 2
Chiou T-J, Wei C-H, Hsieh R-K, Fan FS, Liu J-H, Chen P-M. Comparison of intravenous granisetron with metoclopramide in the treatment of chemotherapy-induced emesis. Chinese Medical Journal (Taipei). 1995;56(1):23–30. | 2
Chiu EKW, Liang R, Lie A, Todd D, Chan TK. Comparison of ondansetron with metoclopramide in the control of emesis induced by moderately emetogenic chemotherapy used for lymphoma and leukaemia patients. Drug Investigation. 1994;8(2):104–109. | 2
Clavel M, Bonneterre J, D’Allens H, Paillarse J-M. Oral ondansetron in the prevention of chemotherapy-induced emesis in breast cancer patients. European Journal of Cancer Part A: General Topics. 1995;31(1):15–19. | 6
Climent MA, Palau J, Ruiz A, et al. The antiemetic efficacy of granisetron plus dexamethasone, haloperidol and loracepam in breast cancer patients treated with high-dose chemotherapy with peripheral blood stem-cell support. Supportive Care in Cancer. 1998;6(3):287–290. | 2
Collis Cea. The final assessment of a randomized double-blind comparative study of ondansetron vs. metoclopramide in the prevention of nausea and vomiting following high-dose upper abdominal irradiation. Clinical Oncology (Royal College of Radiologists). 1991;3(4):241–242. | 5
Conte P, Ricci S, Antonuzzo A, et al. A double-blind randomized study comparing intramuscular (i.m.) granisetron with i.m. granisetron plus dexamethasone in the prevention of delayed emesis induced by cisplatin. The Italian Multicenter Study Group. Anti-Cancer Drugs. 1999;10(5):465–470. | 2
Crucitt MA, Hyman W, Grote T, et al. Efficacy and tolerability of oral ondansetron versus prochlorperazine in the prevention of emesis associated with cyclophosphamide-based chemotherapy and maintenance of health-related quality of life [corrected and republished article originally printed in Clin Ther 1996 May. Clinical Therapeutics. 1996;18(4):778–788. | 6
De Mulder PH, Seynaeve C, Vermorken JB, et al. Ondansetron compared with high-dose metoclopramide in prophylaxis of acute and delayed cisplatin-induced nausea and vomiting. A multicenter, randomized, double-blind, crossover study. Annals of Internal Medicine. 1990;113(11):834–840. | 2
Del Favero A, Ballatori E, Olivieri A, et al. Difference in persistence of efficacy of two antiemetic regimens on acute emesis during cisplatin chemotherapy. Journal of Clinical Oncology. 1993;11(12):2396–2404. | 2
Depierre A, Lebeau B, Chevallier B, Votan B. Efficacy of ondansetron (O), metholprednisolone (M) plus metopimazine (MPZ) in patients previously uncontrolled with dual therapy in cisplatin containing chemotherapy. Ann-Oncol. 1996;7(Suppl 5):134. | 2
Depierre A, Lebeau B, D’Allens H. A comparison of ondansetron with alizapride plus methylprednisolone in the control of cisplatin-induced emesis. Oncology. 1992;49(4):305–311. | 2
Depierre A, Lebeau B, d’Allens H. Comparison between the antiemetic efficacy of Ondansetron (OND) and Alizapride (ALI) plus Methylprednisolone (MPS) in patients receiving high dose Cisplatin in the treatment of lung cancer. European Journal of Cancer. 1991;27(Supp. 2):S172. | 2
Dick GS, Meller ST, Pinkerton CR. Randomised comparison of ondansetron and metoclopramide plus dexamethasone for chemotherapy induced emesis. Archives of Disease in Childhood. 1995;73(3):243–245. | 2
Diehl V. Fractionated chemotherapy - Granisetron or conventional antiemetics? European Journal of Cancer Part A: General Topics. 1992;28(SUPPL. 1):S 21–S 28. | 2
du Bois A, erson H, Lahousen M, et al. Efficacy of ondansetron and metoclopramide (with dexamethasone): in the prevention of carboplatin-induced emesis. Supportive Care in Cancer. 1995;3(343):39. | 2
du Bois A, McKenna CJ, Andersson H, et al. A randomised, double-blind, parallel-group study to compare the efficacy and safety of ondansetron (GR38032F) plus dexamethasone with metoclopramide plus dexamethasone in the prophylaxis of nausea and emesis induced by carboplatin chemotherapy. Oncology. 1997;54(1):7–14. | 2
Esseboom EU, Rojer RA, Borm JJ, Statius van Eps LW. Prophylaxis of delayed nausea and vomiting after cancer chemotherapy. Netherlands Journal of Medicine. 1995;47(1):12–17. | 2
Evans C, Stein RC, Davenport J, Dougherty L, Carruthers L, Coombes RC. Comparison of antiemetic efficacy of ondansetron with dexamethasone plus domperidone in refractory nausea and vomiting in patients receiving non-cisplatinum chemotherapy regimens. Journal of Cancer Research & Clinical Oncology. 1990;116(Suppl):640. | 2
Evans C, Stein RC, Davenport J, Dougherty L, Carruthers L, Coombes RC. Comparison of enti-emetic efficacy of ondansetron with dexamethasone plus domperidone in refractory nausea and vomiting in patients receiving non-cisplatin chemotherapy regimens. European Journal of Cancer. 1991;27(Suppl. 1):S 25. | 2
Fanning J, Hilgers RD. Ondansetron and metoclopramide fail to prevent vomiting secondary to ultra-high-dose cisplatin-carboplatin chemotherapy. Obstetrics and Gynecology. 1994;83(4):601–604. | 2
Fauser AA, Bleiberg H, Chevallier B, et al. A double-blind, randomized, parallel study of IV dolasetron mesilate versus IV metoclopramide in patients receiving moderately emetogenic chemotherapy. Cancer Journal. 1996;9(4):196–202. | 2
Feng FY, Zhang P, He YJ, et al. Comparison of the selective serotonin3 antagonists ramosetron and granisetron in treating acute chemotherapy-induced emesis, nausea, and anorexia: A single-blind, randomized, crossover study. Current Therapeutic Research - Clinical and Experimental. 2000;61(12):901–909. | 2
Feng FY, Zhang P, He YJ, et al. Oral formulations of the selective serotonin3 antagonists ramosetron (intraoral disintegrator formulation) and granisetron hydrochloride (standard tablet) in treating acute chemotherapy-induced emesis, nausea, and anorexia: A multicenter, randomized, single-blind, crossover, comparison study. Current Therapeutic Research - Clinical and Experimental. 2002;63(11):725–735. | 2
Fengyi F, Pin Z, Youjian H, et al. Clinical comparison of the selective serotonin3 antagonists ramosetron and granisetron in treating acute chemotherapy-induced emesis, nausea and anorexia. Chinese Medical Sciences Journal. 2002;17(3):168–172. | 2
Friedman CJ, Burris III HA, Yocom K, Blackburn LM, Gruben D. Oral granisetron for the prevention of acute late onset nausea and vomiting in patients treated with moderately emetogenic chemotherapy. Oncologist. 2000;5(2):136–143. | 2
Frighetto L, Loewen PS, Dolman J, Marra CA. Cost-effectiveness of prophylactic dolasetron or droperidol vs rescue therapy in the prevention of PONV in ambulatory gynecologic surgery. Canadian Journal of Anaesthesia. 1999;46(6):536–543. | 2
Gandara DR. Progress in the control of acute and delayed emesis induced by cisplatin. European Journal of Cancer. 1991;27(SUPPL. 1):S9–S11. | 2
Gebbia V, Testa A, Valenza R, Cannata G, Tirrito ML, Gebbia N. Oral granisetron with or without methylprednisolone versus metoclopramide plus methylprednisolone in the management of delayed nausea and vomiting induced by cisplatin-based chemotherapy: A prospective randomized trial. Cancer. 1995;76(10):1821–1828. | 2
Goldschmidt H, Salwender H, Egerer G, Kempe R, Voigt T. Comparison of oral itasetron with oral ondansetron: Results of a double-blind, active-controlled phase II study in chemotherapy-naive patients receiving moderately emetogenic chemotherapy. Anti-Cancer Drugs. 1997;8(5):436–444. | 2
Hahlen K, Quintana E, Pinkerton CR, Cedar E. A randomized comparison of intravenously administered granisetron versus chlorpromazine plus dexamethasone in the prevention of ifosfamide-induced emesis in children. Journal of Pediatrics. 1995;126(2):309–313. | 2
Hainsworth J, Harvey W, Pendergrass K, et al. A single-blind comparison of intravenous ondansetron, a selective serotonin antagonist, with intravenous metoclopramide in the prevention of nausea and vomiting associated with high-dose cisplatin chemotherapy. Journal of Clinical Oncology. 1991;9(5):721–728. | 2
Handberg J, Wessel V, Larsen L, Herrstedt J, Hansen HH. Randomized, double-blind comparison of granisetron versus granisetron plus prednisolone as antiemetic prophylaxis during multiple-day cisplatin-based chemotherapy. Supportive Care in Cancer. 1998;6(1):63–67. | 2
Hao DZ, Li P, Xie MY, et al. Ondansetron versus primperan in treating nausea and vomiting for chemotherapy coordinated with cisplatin or doxorubicin: 311 phase II clinical randomized controlled trial. Cancer Prevention & Treatment. Issue. 1995;2:17–22. | 2
Henry DW, Marshall JL, Nazzaro D, Fox JL, Leff RD. Stability of cisplatin and ondansetron hydrochloride in admixtures for continuous infusion. Am J Health Syst Pharm. Nov 15 1995;52(22):2570–2573. | 2
Heron JF, Goedhals L, Jordaan JP, Cunningham J, Cedar E. Oral granisetron alone and in combination with dexamethasone: A double-blind randomized comparison against high-dose metoclopramide plus dexamethasone in prevention of cisplatin-induced emesis. Annals of Oncology. 1994;5(7):579–584. | 2
Heron JF. Single-agent oral granisetron for the prevention of acute cisplatin-induced emesis: A double-blind, randomized comparison with granisetron plus dexamethasone and high-dose metoclopramide plus dexamethasone. Seminars in Oncology. 1995;22(4 SUPPL. 10):24–30. | 2
Hiraoka A, Masaoka T, Nagai K, et al. Granisetron oral phase III clinical trial - Study on the inhibitory effect of granisetron for nausea/vomiting induced by chemotherapy for tumors in the hematopoietic organs. Japanese Journal of Cancer and Chemotherapy. 1993;20(12):1835–1841. | 4
Hunter B, Aapro M, Piguet D, et al. The antiemetic efficacy and safety of granisetron compared with metoclopramide plus dexamethasone in patients receiving fractionated chemotherapy over 5 days. The Granisetron Study Group. Journal of Cancer Research and Clinical Oncology. 1993;119(9):555–559. | 2
Ichiki M, Sakurai M, Karato A, Hayashi I. Antiemetic efficacy of granisetron compared with high-dose metoclopramide plus dexamethasone in patients with primary lung cancer receiving chemotherapy: A randomized crossover trial. Journal of Japan Society for Cancer Therapy. 1996;31(5):356–364. | 2
Jacobson SJ, Leclerc JM, Cohn RJ, Pinkerton CR, Nishimura L, Spielberg S. Intravenous granisetron in children receiving highly emetogenic chemotherapy: a double blind, dose-ranging study. European Journal of Clinical Research. 1995;7:145–154. | 6
Jantunen IT, Flander MK, Heikkinen MI, Kuoppala TA, Teerenhovi L, Kataja VV. Comparison of ondansetron with customary treatment in the prophylaxis of nausea and emesis induced by non-cisplatin containing chemotherapy. Acta Oncologica. 1993;32(4):413–415. | 2
Jantunen IT, Kataja VV, Johansson RT. Ondansetron and tropisetron with dexamethasone in the prophylaxis of acute vomiting induced by non-cisplatin-containing chemotherapy. Acta Oncologica. 1992;31(5):573–575. | 2
Johansson S, Steineck G, Hursti T, Fredrikson M, Furst CJ, Peterson C. Effects of ondansetron on chemotherapy-induced acute and delayed emesis - A pilot study. Acta Oncologica. 1991;30(5):649–651. | 2
Jones AL, Cunningham D, Soukop M, et al. Dexamethasone is as effective as Ondansetron in the prophylaxis of emesis induced by moderately emetogenic chemotherapy. European Journal of Cancer. 1991;27(Supp. 2):S285. | 2
Jones AL, Hill AS, Soukop M, et al. Comparison of dexamethasone and ondansetron in the prophylaxis of emesis induced by moderately emetogenic chemotherapy. Lancet. 1991;338(8765):483–487. | 2
Jorgensen M, Victor MA. Antiemetic efficacy of ondansetron and metoclopramide, both combined with corticosteroid, in malignant lymphoma patients receiving non-cisplatin chemotherapy. Acta Oncologica. 1996;35(2):159–163. | 2
Kaasa S, Kvaloy S, Dicato MA, et al. A comparison of ondansetron with metoclopramide in the prophylaxis of chemotherapy-induced nausea and vomiting: A randomized, double-blind study. European Journal of Cancer. 1990;26(3):311–314. | 2
Kaiser R, Sezer O, Papies A, et al. Patient-tailored antiemetic treatment with 5-hydroxytryptamine type 3 receptor antagonists according to cytochrome P-450 2D6 genotypes. Journal of Clinical Oncology. 2002;20(12):2805–2811. | 2
Kaizer L, Warr D, Hoskins P, et al. Effect of schedule and maintenance on the antiemetic efficacy of ondansetron combined with dexamethasone in acute and delayed nausea and emesis in patients receiving moderately emetogenic chemotherapy: A phase III trial by the National Cancer Institute of Canada Clinical Trials Group. Journal of Clinical Oncology. 1994;12(5):1050–1057. | 2
Kandemir EG, Turken O, Onde ME, et al. The role of effective control of acute emesis and comparison of dexamethasone with ondansetron plus dexamethasone in the control of cisplatin-induced delayed emesis. Gulhane Medical Journal. 1999;41(3):278–282. | 2
Kandemir EG, Yaylaci M, Uskent N. Comparison of ondansetron plus dexamethasone with metoclopramide plus dexamethasone in the control of cisplatin-induced delayed emesis. Journal of B.U.ON. 1999;4(3):289–293. | 2
Kang YK, Cheon YK, Im YH, Kim CM, Lee JO, Kang TW. A phase III randomized comparison of MDL (metoclopramide, dexamethasone, and lorazepam) plus granisetron with MDL alone in the prevention of nausea and vomiting associated with multi-day cisplatin-containing chemotherapy. European Journal of Cancer. 1995;31Ÿ(Suppl 5):S259 Abs. 1238. | 2
Kaushal J, Natu MV, Agarwal AK, Deodhar M, Sehgal H, Zachariah A. Comparison of dual versus triple ondansetron combination schedule for the prophylaxis of cisplatin-induced delayed emesis in patients with cancer. Asia Pacific Journal of Pharmacology. 1998;13(1):25–30. | 2
Khamales S, Bethune-Volters A, Chidiac J, Bensaoula O, Delgado A, Di Palma M. A randomized, double-blind trial assessing the efficacy and safety of sublingual metopimazine and ondansetron in the prophylaxis of chemotherapy-induced delayed emesis.[erratum appears in Anticancer Drugs. 2006 Jun;17(5):599 Note: Khamales, Slimane [added]]. Anti-Cancer Drugs. Feb 2006;17(2):217–224. | 3
Kigawa J, Minagawa Y, Itamochi H, Cheng X, Okada M, Terakawa N. Combination effect of granisetron and methylprednisolone for preventing emesis induced by cytotoxic agents. Gynecologic and Obstetric Investigation. 1997;43(3):195–199. | 2
Kim H, Rosenberg SA, Steinberg SM, Cole DJ, Weber JS. A randomized double-blinded comparison of the antiemetic efficacy of ondansetron and droperidol in patients receiving high-dose interleukin-2. Journal of Immunotherapy. 1994;16(1):60–65. | 2
Koo WH, Ang PT. Role of maintenance oral dexamethasone in prophylaxis of delayed emesis caused by moderately emetogenic chemotherapy. Annals of Oncology. 1996;7(1):71–74. | 2
Koralewski P, Karczmarek-Borowska B, Cegielski W, Nawara I, Urbanska-Gasiorowska M. Effectiveness of oral ondansetron in the management of nausea and vomiting induced by moderately emetogenic chemotherapy. Nowotwory. 2001;51(6):579–583. | 1
Koseoglu V, Kurekci AE, Sarici U, Atay AA, Ozcan O, Sorici U. Comparison of the efficacy and side-effects of ondansetron and metoclopramide-diphenhydramine administered to control nausea and vomiting in children treated with antineoplastic chemotherapy: a prospective randomized study.[erratum appears in Eur J Pediatr 1999 Feb;158(2):168 Note: Sorici U[corrected to Sarici U]]. European Journal of Pediatrics. 1998;157(10):806–810. | 2
Kunkler I, Rushby P, Barley V, Newman H, Slater A, Khanna S. A randomised compaprison of Ondansetron with customary anti-emetics in palliative upper abdominal irradiation. Br-J-Cancer. 1994;70(Suppl. XXII):35. | 5
Labar B, Mrsic M, Nemet D, et al. Ondansetron for prophylaxis of nausea and vomiting after bone marrow transplantation. Libri Oncologici. 1995;24(3):131–135. | 2
Lachaine J, Laurier C, Langleben A, Vaillant L. Cost-effectiveness and quality of life evaluation of ondansetron and metoclopramide for moderately emetogenic chemotherapy regimens in breast cancer. Critical Reviews in Oncology/Hematology. 1999;32(2):105–112. | 6
Lazarus HM, Bryson JC, Lemon E, Pritchard JF, Blumer J. Antiemetic efficacy and pharmacokinetic analyses of the serotonin antagonist ondansetron (GR 38032F) during multiple-day chemotherapy with cisplatin prior to autologous bone marrow transplantation. Journal of the National Cancer Institute. 1990;82(22):1776–1778. | 2
Le Bonniec M, Madelaine I, Dieras V, Extra JM, Romain D, Marty M. Results of a single blinded randomized study with cross-over of granisetron and standard anti-emetics in the prophylaxis of chemotherapy-induced emesis. Ann-Oncol. 1990;1(Suppl):112. | 2
Levitt M, Warr D, Yelle L, et al. Ondansetron compared with dexamethasone and metoclopramide as antiemetics in the chemotherapy of breast cancer with cyclophosphamide, methotrexate, and fluorouracil. New England Journal of Medicine. 1993;328(15):1081–1084. | 2
Lim AK, Haron MR, Yap TM. Ondansetron against metoclopramide/dexamethasone--a comparative study. Medical Journal of Malaysia. 1994;49(3):231–238. | 2
Lu ZM, Gu FY. The effect of ondansetron and meocloprarnide was compared in the prevention of emesis. China Journal of Cancer Prevention and Treatment. 2002;9(5):536–537. | 2
Luisi FA, Petrilli AS, Tanaka C, Caran EM. Contribution to the treatment of nausea and emesis induced by chemotherapy in children and adolescents with osteosarcoma. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2006;124(2):61–65. | 2
Manolas G, Alexopoulos CG, Vaslamatzis M, Papacharalambous S, Papachristodoulou A, Xynogalos S. A comparative study of the effectiveness of ondansetron vs hig dose metoclopramide + dexamethasone in the anti-emesis during high dose cisplatinum II (CDDP) chemotherapy. Ann-Oncol. 1992;3(Suppl 5):186. | 2
Mantovani G, Maccio A, Curreli L, et al. Comparison of oral 5-HT3-receptor antagonists and low-dose oral metoclopramide plus i.m. dexamethasone for the prevention of delayed emesis in head and neck cancer patients receiving high-dose cisplatin. Oncology Reports. 1998;5(1):273–280. | 2
Manullang TR, Viscomi CM, Pace NL. Intrathecal fentanyl is superior to intravenous ondansetron for the prevention of perioperative nausea during cesarean delivery with spinal anesthesia. Anesthesia and Analgesia. 2000;90(5):1162–1166. | 2
Manusirivithaya S, Isariyodom P, Chareoniam V, Sungsab D. Comparison of ondansetron-dexamethasone-lorazepam versus metoclopramide-dexamethasone-lorazepam in the control of cisplatin induced emesis. Journal of the Medical Association of Thailand. 2001;84(7):966–972. | 2
Marry M. A singled-blind randomized comparator study with crossover of granisetron, a selective 5-HT3 antagonist versus standard anti-emetics in the prophyhlaxis og chemotherapy-induced emesis. Ann-Oncol. 1992;3(Suppl 1):157. | 2
Marschner N, Adler M, Nagel GA, Christmann D. Double-blind randomised trial of the anti-emetic efficacy and safety of ondansetron and metoclopramide in advance breast cancer patients treated with epirubicin and cyclophosphamide. European Journal of Cancer. 1991;27(Suppl. 1):S 26. | 2
Marschner N, Adler M, Nagel GA, Christmann D. Double-blind randomized trial of the anti-emetic efficacy and safety of ondansetron and metoclopramide in advanced breast cancer patients treated with epirubicin and cyclophosphamide. Journal of Cancer Research & Clinical Oncology. 1990;116(Suppl):641. | 2
Marschner NW, Adler M, Nagel GA, Christmann D, Fenzl E, Upadhyaya B. Double-blind randomised trial of the antiemetic efficacy and safety of ondansetron and metoclopramide in advanced breast cancer patients treated with Epirubicin and cyclophosphamide. European Journal of Cancer. 1991;27(9):1137–1140. | 2
Marty M, Clavreul G, Delas N, et al. Curative efficacy of ondansetron against nausea and emesis induced by anticancer drugs: A study versus metoclopramide. Sem Hop. 1994;70(31–32):985–988. | 2
Marty M, Paillarse JM, the French Study G. Efficacy of ondansetron (ONC) and metoclopramide (MCP) as an intervention treatment in patients experiencing emesis. Ann-Oncol. 1992;3(Suppl 5):184. | 2
Marty M, Pouillart P, Scholl S, et al. Comparison of the 5-hydroxytryptamine3 (serotonin) antagonist ondansetron (GR 38032F) with high-dose metoclopramide in the control of cisplatin-induced emesis. New England Journal of Medicine. 1990;322(12):816–821. | 2
Marty M. A comparative study of the use of granisetron, a selective 5-HT3 antagonist, versus a standard anti-emetic regimen of chlorpromazine plus dexamethasone in the treatment of cytostatic-induced emesis. Eur J Cancer. 1990;26(SUPPL. 1):S28–S32. | 2
Marty M. A comparison of granisetron as a single agent with conventional combination antiemetic therapies in the treatment of cystostatic-induced emesis. European Journal of Cancer Part A: General Topics. 1992;28(SUPPL. 1):S 12–S 16. | 2
Mehta NH, Reed CM, Kuhlman C, Weinstein HJ, Parsons SK. Controlling conditioning-related emesis in children undergoing bone marrow transplantation. Oncology Nursing Forum. 1997;24(9):1539–1544. | 2
Miyajima Y, Numata S-I, Katayama I, Horibe K. Prevention of chemotherapy-induced emesis with granisetron in children with malignant diseases. American Journal of Pediatric Hematology/Oncology. 1994;16(3):236–241. | 2
Munstedt K, Milch W, Blauth-Eckmeyer E, Spanle A, Vahrson A, Reimer C. Prevention of cisplatinum-induced delayed emesis and nausea. Onkologie. 1995;18(1):23–26. | 1
Mustacchi G, Ceccherini R, Leita ML, Sandri P, Milani S, Carbonara T. The combination of Metoclopramide, Methylprednisolone and Ondansetron against antiblastic-delayed emesis: A randomised phase II study. Anticancer Research. 1997;17(2 B):1345–1348. | 2
Mustacchi G, Ceccherini R, Milani S, Sandri P, Leita ML. Ondansetron (O), metoclopramide (M) and methylprednisolone (MP) p.o.: A good combination against delayed emesis in highly emetogenic chemotherapy. Ann-Oncol. 1996;7(Suppl 5):140. | 2
Mylonakis N, Tsavaris N, Karabelis A, Stefis J, Kosmidis P. A randomized comparative study of antiemetic activity of Ondansetron (Ond) vs Tropisetron (Tr) in patients receiving moderately emetogenic chemotherapy. Supportive Care in Cancer. 1996;4(252). | 2
Naruse I, Minato K, Tsuchiya S, et al. Granisetron plus methylprednisolone versus granisetron alone in prevention of emesis associated with cisplatin-containing chemotherapies. Cancer Journal. 1998;11(2):82–85. | 2
Navari RM, Province WS, Perrine GM, Kilgore JR. Comparison of intermittent ondansetron versus continuous infusion metoclopramide used with standard combination antiemetics in control of acute nausea induced by cisplatin chemotherapy. Cancer. 1993;72(2):583–586. | 2
Nicolai N, Mangiarotti B, Salvioni R, Piva L, Faustini M, Pizzocaro G. Dexamethasone plus ondansetron versus dexamethasone plus alizapride in the prevention of emesis induced by cisplatin-containing chemotherapies for urological cancers. European Urology. 1993;23(4):450–456. | 2
Numbenjapon T, Mongkonsritragoon W, Prayoonwiwat W, Sriswasdi C, Leelasiri A. Comparative study of low-dose oral granisetron plus dexamethasone and high-dose metoclopramide plus dexamethasone in prevention of nausea and vomiting induced by CHOP-therapy in young patients with non-Hodgkin’s lymphoma. Journal of the Medical Association of Thailand. 2002;85(11):1156–1163. | 2
Ogihara M, Suzuki T, Yanagida T, Tsuruya Y, Ishibashi K, Yamaguchi O. Clinical assessment of granisetron and methyl-prednisolone as a prophylactic antiemetic in cisplatin-induced delayed emesis. Japanese Journal of Clinical Urology. 1999;53(2):141–145. | 2
Ohmatsu H, Eguchi K, Shinkai T, et al. A randomized cross-over study of high-dose metoclopramide plus dexamethasone versus granisetron plus dexamethasone in patients receiving chemotherapy with high-dose cisplatin. Japanese Journal of Cancer Research. 1994;85(11):1151–1158. | 2
Ohwada M, Suzuki M, Ogawa S, Tamada T, Sato I. Efficacy and tolerability of granisetron with betamethasone, an antiemetic combination, in gynecologic cancer patients receiving cisplatin. Current Therapeutic Research - Clinical and Experimental. 1995;56(10):1059–1065. | 2
Okamoto S, Takahashi S, Tanosaki R, et al. Granisetron in the prevention of vomiting induced by conditioning for stem cell transplantation: A prospective randomized study. Bone Marrow Transplantation. 1996;17(5):679–683. | 2
Olver IN. Aprepitant in antiemetic combinations to prevent chemotherapy-induced nausea and vomiting. Int J Clin Pract. Feb 2004;58(2):201–206. | 2
Ossi M, Anderson E, Freeman A. 5-HT3 receptor antagonists in the control of cisplatin-induced delayed emesis. Oncology. 1996;53(SUPPL. 1):78–85. | 2
Pizzocaro G, Salvioni R, Nicolai N, Spino E. Ondansetron plus Dexamethasone (DEX) versus Alyzapride plus DEX in the prevention of vomiting in Cisplatin based chemotherapy: preliminary results. European Journal of Cancer. 1991;27(Supp. 2):S294. | 2
Plasencia-Mota A, Garcia-Vidrios V, Rivas-Vera S, Velez-Rodriguez S, Silveyra-Gomez C, Hernandez-Hernandez A. An evaluation of the effectiveness of ondasetron vs. triple antiemetic drug in patients with hematologic neoplasias. Sangre. 1993;38(1):85. | 2
Prentice HG, Cunningham S, Gandhi L, Cunningham J, Collis C, Hamon MD. Granisetron in the prevention of irradiation-induced emesis. Bone Marrow Transplantation. 1995;15(3):445–448. | 6
Prentice HG. Efficacy and safety of intravenous granisetron compared with a standard anti-emetic therapy in patients undergoing total body irradiation (TBI) prior to bone marrow transplantation (BMT). Ann-Oncol. 1992;3(Suppl 5):186. | 2
Priestman TJ, Roberts JT, Lucraft H, et al. Interim Report of a Prospective Randomized Double-Blind Trial Comparing Ondasetron and Prochlorperazine in the Prevention of Radiation-Induced Emesis. (Abstract). Clinical Oncology. 1991;3(5):298. | 5
Priestman TJ, Roberts JT, Lucraft H, et al. Results of a randomized, double-blind comparative study of ondansetron and metoclopramide in the prevention of nausea and vomiting following high-dose upper abdominal irradiation. Clinical Oncology (Royal College of Radiologists). 1990;2(2):71–75. | 6
Priestman TJ, Roberts JT, Upadhyaya BK. A prospective randomized double-blind trial comparing ondansetron versus prochlorperazine for the prevention of nausea and vomiting in patients undergoing fractionated radiotherapy. Clinical Oncology. 1993;5(6):358–363. | 6
Priestman TJ, Roberts JT, Upadhyaya BK. Randomised, double-blind trial of ondansetron (OND) and prochlorperazine (PCP) in the prevntion of fractionated radiotherapy (RT). Ann-Oncol. 1992;3(Suppl 5):185. | 5
Priestman TJ. Clinical studies with ondansetron in the control of radiation-induced emesis. European Journal of Cancer and Clinical Oncology. 1989;25(SUPPL. 1):S29–S33. | 6
Rath U, Upadhyaya BK, Arechavala E, et al. Role of ondansetron plus dexamethasone in fractionated chemotherapy. Oncology. 1993;50(3):168–172. | 2
Raynov J, Danon S, Valerianova Z. Control of acute emesis in repeated courses of moderately emetogenic chemotherapy. Journal of B.U.ON. 2002;7(1):57–60. | 2
Roila F, Ballatori E, Contu A, et al. Ondansetron (OND) vs metoclopramide (MTC) both combined with dexametasone (DEX) in the prevention of cisplatin (CDDP)-induced delayed emesis. Tumori. 1996;82(60). | 2
Roila F, Ballatori E, De Angelis V, et al. Dexamethasone, granisetron, or both for the prevention of nausea and vomiting during chemotherapy for cancer. New England Journal of Medicine. 1995;332(1):1–5. | 2
Roila F, Tonato M, Ballatori E, et al. Ondansetron + dexamethasone vs metoclopramide + dexamethasone + diphenhydramine in prevention of cisplatin-induced emesis. Lancet. 1992;340(8811):96–99. | 2
Roila F, Tonato M, Favalli G, et al. Persistence of efficacy of Ondansetron (OND) plus Dexamethasone (DEX) vs. Metoclopramide (MTC) plus DEX and Diphenhydramine (DIP) in acute emesis during three consecutive cycles of Cisplatin (CDDP) chemotherapy (CT). European Journal of Cancer. 1993;29Ÿ(Supp. 6):S207. | 2
Roila F, Tonato M, Favalli G, Scarfone G, Cognetti F, Buzzi F. A multicenter double-blind study comparing the antiemetic efficacy and safety of ondansetron (OND) plus dexamethasone (dex) vs metoclopramide (MTC) plus dex and diphenhydramine (DIP) in cisplatin (CDDP) treated cancer patients (Pts). Ann-Oncol. 1992;3(Suppl 5):183. | 2
Roila F. Ondansetron plus dexamethasone compared to the ‘standard’ metoclopramide combination. Oncology. 1993;50(3):163–167. | 2
Roila F. Persistence of efficacy of three antiemetic regimens and prognostic factors in patients undergoing moderately emetogenic chemotherapy. Journal of Clinical Oncology. 1995;13(9):2417–2426. | 2
Sandoval C, Corbi D, Strobino B, Ozkaynak MF, Tugal O, Jayabose S. Randomized double-blind comparison of single high-dose ondansetron and multiple standard-dose ondansetron in chemotherapy-naive pediatric oncology patients. Cancer Investigation. 1999;17(5):309–313. | 2
Sands R, Roberts JT, Marsh M, Gill A. Low dose ondansetron and dexamethasone: a cost effective alternative to high dose metoclopramide/dexamethasone/lorazepam in the prevention of acute cisplatin induced emesis. Clin Oncol (R Coll Radiol). Jan 1992;4(1):67. | 2
Sigsgaard T, Herrstedt J, Andersen LJ, et al. Granisetron compared with prednisolone plus metopimazine as anti-emetic prophylaxis during multiple cycles of moderately emetogenic chemotherapy. British Journal of Cancer. 1999;80(3–4):412–418. | 2
Sigsgaard T, Herrstedt J, Christensen P, Andersen O, Dombernowsky P. Antiemetic efficacy of combination therapy with granisetron plus prednisolone plus the dopamine D2 antagonist metopimazine during multiple cycles of moderately emetogenic chemotherapy in patients refractory to previous antiemetic therapy. Supportive Care in Cancer. 2000;8(3):233–237. | 2
Sismondi P, Danese S, Giardina G, et al. Antiemetic efficacy of granisetron in patients with gynecological malignancies. Anti-Cancer Drugs. 1997;8(3):225–230. | 2
Skarlos DV, Pavlidis N, Fountzilas G, et al. Ondansetron (O) vs. Metoclopramide in Carboplatinum containing regimens. European Journal of Cancer. 1991;27(Supp. 2):S296. | 2
Sledge GW, Jr., Einhorn L, Nagy C, House K. Phase III double-blind comparison of intravenous ondansetron and metoclopramide as antiemetic therapy for patients receiving multiple-day cisplatin-based chemotherapy. Cancer. 1992;70(10):2524–2528. | 2
Smith IE. Anti-emetic treatment with granisetron in patients receiving moderately emetogenic chemotherapy. European Journal of Clinical Research. 1994;5(-):193–202. | 2
Sontakke S, Thawani V, Naik MS. Ginger as an antiemetic in nausea and vomiting induced by chemotherapy: A randomized, cross-over, double blind study. Indian Journal of Pharmacology. 2003;35(1):32–36. | 2
Soukop M, McQuade B, Hunter E, et al. Ondansetron compared with metoclopramide in the control of emesis and quality of life during repeated chemotherapy for breast cancer. Oncology. 1992;49(4):295–304. | 6
Soukop M. Management of cyclophosphamide-induced emesis over repeat courses. Oncology. 1996;53(SUPPL. 1):39–45. | 5
Stiakaki E, Savvas S, Lydaki E, et al. Ondansetron and tropisetron in the control of nausea and vomiting in children receiving combined cancer chemotherapy. Pediatric Hematology and Oncology. 1999;16(2):101–108. | 2
Sundstrom GM, Wahlin A. Comparison of efficacies of ondansetron and dixyrazine for prophylaxis of emesis during induction treatment in acute myelogenous leukemia - A pilot study. Acta Oncologica. 1997;36(2):229–230. | 2
Sykes AJ, Kiltie AE, Stewart AL. Ondansetron versus a chlorpromazine and dexamethasone combination for the prevention of nausea and vomiting: A prospective, randomised study to assess efficacy, cost effectiveness and quality of life following single-fraction radiotherapy. Supportive Care in Cancer. 1997;5(6):500–503. | 6
Terrey JP, Aapro M, Kirchner Z, Alberto P. Patient preference of antiemetic treatment: a placebo controlled double blind comparison of granisetron with granisetron plus dexamethasone. European Journal of Cancer. 1995;31Ÿ(Suppl 5):S186 Abs. 895. | 2
Tonato M. Ondansetron plus dexamethasone: An effective combination in high-dose cisplatin therapy. European Journal of Cancer. 1991;27(SUPPL. 1):S12–S14. | 2
Tsavaris N, Charalambidis G, Ganas N, et al. Ondansetron versus metoclopramide as antiemetic treatment during cisplatin-based chemotherapy. A prospective study with special regard to electrolyte imbalance. Acta Oncologica. 1995;34(2):243–246. | 2
Tsavaris N, Charalambidis G, Pagou M, et al. Comparison of ondansentron (GR 38032F) versus ondansentron plus alprazolam as antiemetic prophylaxis during cisplatin-containing chemotherapy. American Journal of Clinical Oncology: Cancer Clinical Trials. 1994;17(6):516–521. | 2
Tsavaris N, Mylonakis N, Bacoyiannis C, Katsikas M, Lioni A, Kosmidis P. Comparison of ondansentron versus ondansentron plus methylprednisolone as antiemetic prophylaxis during cisplatin-containing chemotherapy. Journal of Pain and Symptom Management. 1994;9(4):254–258. | 2
Tsavaris NB, Koufos C, Katsikas M, Dimitrakopoulos A, Athanasiou E, Linardaki G. Antiemetic prophylaxis with ondansetron and methylprednisolone vs metoclopramide and methylprednisolone in mild and moderately emetogenic chemotherapy. Journal of Pain and Symptom Management. 1999;18(3):218–222. | 2
Tsukada H, Hirose T, Yokoyama A, Kurita Y. Randomised comparison of ondansetron plus dexamethasone with dexamethasone alone for the control of delayed cisplatin-induced emesis. European Journal of Cancer. 2001;37(18):2398–2404. | 2
Tsukuda M, Furukawa S, Kokatsu T, Enomoto H, Kubota A, Furukawa M. Comparison of granisetron alone and granisetron plus hydroxyzine hydrochloride for prophylactic treatment of emesis induced by cisplatin chemotherapy. European Journal of Cancer Part A: General Topics. 1995;31(10):1647–1649. | 2
Tsukuda M, Kokatsu T, Furukawa S, et al. Comparison of granisetron alone and granisetron plus hydroxyzine hydrochloride for the prophylactic treatment of emesis induced by cisplatin-containing chemotherapy. Japanese Journal of Cancer and Chemotherapy. 1993;20(13):2037–2041. | 2
Uchida K, Akaza H, Shimazui T, et al. Comparison of clinical effects between granisetron alone and combination of granisetron and methylprednisolone against the nausea and vomiting induced by CDDP chemotherapy comparative study by the cross-over trial. Japanese Journal of Cancer and Chemotherapy. 1996;23(1):81–86. | 2
Ummenhofer W, Frei FJ, Urwyler A, Kern C, Drewe J. Effects of ondansetron in the prevention of postoperative nausea and vomiting in children. Anesthesiology. 1994;81(4):804–810. | 2
Victor MA, Jorgensen M. Antiemetic efficacy of Ondansetron and Corticosteroid in patients receiving chemotherapy for malignant lymphoma. European Journal of Cancer. 1993;29Ÿ(Supp. 6):S210. | 2
Wan-Yong Z. Combined use of ondansetron and other anti-emetics to control cisplatin-induced nausea and vomiting. Chinese Journal of Oncology. 1993;15(2):118–121. | 2
Warr D, Wilan A, Venner P, et al. A randomised, double-blind comparison of granisetron with high-dose metoclopramide, dexamethasone and diphenhydramine for cisplatin-induced emesis. An NCI Canada Clinical Trials Group Phase III Trial. European Journal of Cancer. 1992;29A(1):33–36. | 2
Warr D, Willan A, Fine S, et al. Superiority of granisetron to dexamethasone plus prochlorperazine in the prevention of chemotherapy-induced emesis. Journal of the National Cancer Institute. 1991;83(16):1169–1173. | 2
Xynogalos S, Vaslamatzis M, Alexopoulos CG. Ondansetron (ODS) + metoclopramide (MTP) + dexamethasone (DXM) vs ondansetron + dexamethasone during CDDP based chemotherapy (CT). European Journal of Cancer. 1995;31Ÿ(Suppl 5):A261 Abs 1252. | 2
Yamaguchi T, Niitani H, Hasegawa K, Furue H. Randomized comparitor study with crossover of Granisetron versus high-dose Methylprednisolone (MP) in the treatment of Cisplatin-induced emesis. European Journal of Cancer. 1991;27(Supp. 2):S296. | 2
Yoshizawa M, Chida M, Ichioka M, et al. Prevention of nausea and vomiting induced by chemotherapy with cisplatin plus vindesine in non-small cell lung cancer patients: A prospective randomized trial comparing granisetron with granisetron plus moderate-dose methylprednisolone. Japanese Journal of Lung Cancer. 1995;35(4):417–423. | 2
Zaluski J, Puistola U, Madej G. Ondansetron plus dexamethasone, ondansetron and tropisetron in the prophylaxis of cisplatin-induced acute emesis: a multicentre, double-blind, randomized, parallel group study. The Emesis Study Group. European Journal of Clinical Research. 1997;9:21–31. | 2
Placebo-controlled trials
Anonymous. Dexamethasone alone or in combination with ondansetron for the prevention of delayed nausea and vomiting induced by chemotherapy. The Italian Group for Antiemetic Research. New England Journal of Medicine. 2000;342(21):1554–1559. | 6
Barrenetxea G, Schneider J, Mar Centeno M, Romero H, De la Rica M, Rodriguez-Escudero FJ. Chemotherapy-induced emesis: Management of early and delayed emesis in milder emetogenic regimens. Cancer Chemotherapy and Pharmacology. 1996;38(5):471–475. | 6
Beck T, York M, Chang A, et al. Oral ondansetron 8 MG BID is as effective as 8 MG TID in the prevention of nausea and vomiting associated with cyclophosphamide-based chemotherapy. Breast Cancer Research & Treatment. 1996;37(Suppl):92 | 5
Beck TM, Ciociola AA, Jones SE, et al. Efficacy of oral ondansetron in the prevention of emesis in outpatients receiving cyclophosphamide-based chemotherapy. The Ondansetron Study Group. Annals of Internal Medicine. 1993;118(6):407–413. | 2
Beck TM. Efficacy of ondansetron tablets in the management of chemotherapy-induced emesis: Review of clinical trials. Seminars in Oncology. 1992;19(6 SUPPL. 15):20–25. | 2
Beck TM. The pattern of emesis following high-dose cyclophosphamide and the anti-emetic efficacy of ondansetron. Anti-Cancer Drugs. 1995;6(2):237–242. | 2
Bey P, Wilkinson PM, Claverie N. IV dolasetron mesilate in the prevention of radiotherapy-induced nausea and vomiting. Supportive Care in Cancer. 1995;3(342). | 5
Bey P, Wilkinson PM, Resbeut M, et al. A double-blind, placebo-controlled trial of i.v. dolasetron mesilate in the prevention of radiotherapy-induced nausea and vomiting in cancer patients. Supportive Care in Cancer. 1996;4(5):378–383. | 6
Buser KS, Joss RA, Piquet D, et al. Oral ondansetron in the prophylaxis of nausea and vomiting induced by cyclophosphamide, methotrexate and 5-fluorouracil (CMF) in women with breast cancer. Results of a prospective, randomized, double-blind, placebo-controlled study. Annals of Oncology. 1993;4(6):475–479. | 2
Cherian VT, Smith I. Prophylactic ondansetron does not improve patient satisfaction in women using PCA after Caesarean section. British Journal of Anaesthesia. 2001;87(3):502–504. | 6
Cieslak GD, Watcha MF, Phillips MB, Pennant JH. The dose-response relation and cost-effectiveness of granisetron for the prophylaxis of pediatric postoperative emesis. Anesthesiology. 1996;85(5):1076–1085. | 6
Creed M, Brogden J, Ames M, Bryson J. Oral ondansetron (OND) for the prevention of acute nausea and vomiting (N/V) in highly emetogenic cisplatin (CDDP)-based chemotherapy regimens. Supportive Care in Cancer. 1999;7(176):44. | 2
Cubeddu LX, Hoffman IS, Fuenmayor NT, Finn AL. Antagonism of serotonin S3 receptors with ondansetron prevents nausea and emesis induced by cyclophosphamide-containing chemotherapy regimens. Journal of Clinical Oncology. 1990;8(10):1721–1727. | 2
Cubeddu LX, Hoffmann IS, Fuenmayor NT, Finn AL. Efficacy of ondansetron (GR 38032F) and the role of serotonin in cisplatin-induced nausea and vomiting. New England Journal of Medicine. 1990;322(12):810–816. | 2
Cubeddu LX, Pendergrass K, Ryan T, et al. Efficacy of oral ondansetron, a selective antagonist of 5-HT3 receptors, in the treatment of nausea and vomiting associated with cyclophosphamide-based chemotherapies. American Journal of Clinical Oncology: Cancer Clinical Trials. 1994;17(2):137–146. | 2
Cupissol DR, Serrou B, Caubel M. The efficacy of granisetron as a prophylactic anti-emetic and intervention agent in high-dose cisplatin-induced emesis. European Journal of Cancer. 1990;26(1). | 2
DiBenedetto J, Cubeddu L, Ryan T, Kish J, Sciortino D, Beall C. Twice daily oral ondansetron effectively prevents nausea and vomiting associated with cyclophosphamide-doxorubicin-based chemotherapy. Supportive Care in Cancer. 1995;3(342):35. | 5
DiBenedetto J, Jr., Cubeddu LX, Ryan T, et al. Ondansetron for nausea and vomiting associated with moderately emetogenic cancer chemotherapy. Clinical Therapeutics. 1995;17(6):1091–1098. | 2
du Bois A, Meerpohl HG, Vach W, Kommoss FG, Fenzl E, Pfleiderer A. Course, patterns, and risk-factors for chemotherapy-induced emesis in cisplatin-pretreated patients: a study with ondansetron. European Journal of Cancer. 1992;28(2–3):450–457. | 2
El Shobaki AM, Bondok RS, Yakoub AM. Efficacy of intravenous granisetron versus placebo in the prophylaxis of postoperative nausea and vomiting after infratentorial craniotomy: A double-blind randomised study. Egyptian Journal of Anaesthesia. 2003;19(3):297–304. | 2
Franzen L, Nyman J, Hagberg H, et al. A randomised placebo controlled study with ondansetron in patients undergoing fractionated radiotherapy. Annals of Oncology. 1996;7(6):587–592. | 6
Franzen L. Ondansetron antiemetic prophylaxis in patients undergoing fractionated radiotherapy. European Journal of Cancer. 1995;31Ÿ(Suppl 5):S36 Abs. 158. | 5
Fujii Y, Tanaka H, Toyooka H. Granisetron prevents nausea and vomiting during spinal anaesthesia for caesarean section. Acta Anaesthesiologica Scandinavica. 1998e;42(3):312–315. | 2
Fujii Y, Tanaka H, Toyooka H. Prophylactic antiemetic therapy with granisetron-dexamethasone combination in women undergoing breast surgery. Acta Anaesthesiologica Scandinavica. 1998;42(9):1038–1042. | 2
Gandara DR, Harvey WH, Monaghan GG, Perez EA, Hesketh PJ. Delayed emesis following high-dose cisplatin: A double-blind randomised comparative trial of ondansetron (GR 38032F) versus placebo. European Journal of Cancer Part A: General Topics. 1992;29(SUPPL. 1):S35–S38. | 2
Gandara DR, Harvey WH, Monaghan GG, Perez EA, Hesketh PJ. Delayed emesis following high-dose cisplatin: a double-blind randomised comparative trial of ondansetron (GR 38032F) versus placebo. European Journal of Cancer. 1993;1(8). | 2
Goedhals L, Heron J-F, Kleisbauer J-P, Pagani O, Sessa C. Control of delayed nausea and vomiting with granisetron plus dexamethasone or dexamethasone alone in patients receiving highly emetogenic chemotherapy: A double-blind, placebo-controlled, comparative study. Annals of Oncology. 1998;9(6):661–666. | 2
Green JA, Watkin SW, Hammond P, Griggs J, Challoner T. The efficacy and safety of GR38032F in the prophylaxis of ifosfamide-induced nausea and vomiting. Cancer Chemotherapy and Pharmacology. 1989;24(2):137–139. | 2
Herrstedt J, Muss HB, Warr DG, et al. Efficacy and tolerability of aprepitant for the prevention of chemotherapy-induced nausea and emesis over multiple cycles of moderately emetogenic chemotherapy. Cancer. Oct 1 2005;104(7):1548–1555. | 6
Hesketh PJ, Grunberg SM, Gralla RJ, et al. The oral neurokinin-1 antagonist aprepitant for the prevention of chemotherapy-induced nausea and vomiting: a multinational, randomized, double-blind, placebo-controlled trial in patients receiving high-dose cisplatin--the Aprepitant Protocol 052 Study Group. Journal of Clinical Oncology. 2003;21(22):4112–4119. | 6
Huang F, Zhang ML. Effect of ondansetron in prevention of nausea and vomiting induced by cancer chemotherapy. Shanxi Medical Journal. 2001;30(9):546–548. | 1
Ikeda M, Taguchi T, Ota K, et al. Evaluatin of SN-307 (ondansetron), given intravenously for the treatment of nausea and vomiting caused by anticancer drugs including cisplatin - A placebo-controlled, double-blind comparative study. Jpn J Cancer Chemother. 1992;19(12):2071–2084. | 2
Kolecki P, Wachowiak J, Beshari SE. Ondansetron as an effective drug in prophylaxis of chemotherapy-induced emesis in children. Acta Haematologica Polonica. 1993;24(2):115–122. | 6
Lajolo PP, de Camargo B, del Giglio A. Omission of day 2 of antiemetic medications is a cost saving strategy for improving chemotherapy-induced nausea and vomiting control: results of a randomized phase III trial. Am J Clin Oncol. Feb 2009;32(1):23–26. | 6
Lanciano R, Sherman DM, Michalski J, Preston AJ, Yocom K, Friedman C. The efficacy and safety of once-daily Kytril(registered trademark) (Granisetron Hydrochloride) tablets in the prophylaxis of nausea and emesis following fractionated upper abdominal radiotherapy. Cancer Investigation. 2001;19(8):763–772. | 6
LeBourgeois JP, McKenna CJ, Coster B, et al. Efficacy of an ondansetron orally disintegrating tablet: A novel oral formulation of this 5-HT3 receptor antagonist in the treatment of fractionated radiotherapy-induced nausea and emesis. Clinical Oncology. 1999;11(5):340–347. | 6
Lewis LC, Flynn C, Boyea G, et al. Phase III prospective randomized clinical trial utilizing oral granisetron hydrochloride (Kytril) for control of radiation induced nausea and vomiting when treating the abdomino/pelvic area [abstract]. International Journal of Radiation Oncology Biology Physics. 2002;54(2 Suppl):306–307. | 6
Liberman MA, Howe S, Lane M. Ondansetron versus placebo for prophylaxis of nausea and vomiting in patients undergoing ambulatory laparoscopic cholecystectomy. American Journal of Surgery. 2000;179(1):60–62. | 2
Marschner N. Anti-emetic control with ondansetron in the chemotherapy of breast cancer: A review. European Journal of Cancer. 1991;27(SUPPL. 1):S15–S17. | 5
McCrea JB, Majumdar AK, Goldberg MR, et al. Effects of the neurokinin1 receptor antagonist aprepitant on the pharmacokinetics of dexamethasone and methylprednisolone. Clinical Pharmacology & Therapeutics. 2003;74(1):17–24. | 4
McKenzie R, Uy NT, Riley TJ, Hamilton DL. Droperidol/ondansetron combination controls nausea and vomiting after tubal banding [published erratum appears in Anesth Analg 1997 Mar;84(3):704] Anesthesia & Analgesia. 1996;83(6):1218–1222. | 2
Navari RM, Madajewicz S, Anderson N, et al. Oral ondansetron for the control of cisplatin-induced delayed emesis: a large, multicenter, double-blind, randomized comparative trial of ondansetron versus placebo. Journal of Clinical Oncology. 1995;13(9):2408–2416. | 2
Olver I, Paska W, Depierre A, et al. A multicentre, double-blind study comparing placebo, ondansetron and ondansetron plus dexamethasone for the control of cisplatin-induced delayed emesis. Annals of Oncology. 1996;7(9):945–952. | 2
Parker RI, Prakash D, Mahan RA, Giugliano DM, Atlas MP. Randomized, double-blind, crossover, placebo-controlled trial of intravenous ondansetron for the prevention of intrathecal chemotherapy-induced vomiting in children. Journal of Pediatric Hematology/Oncology. 2001;23(9):578–581. | 6
Rung GW, Claybon L, Hord A, et al. Intravenous ondansetron for postsurgical opioid-induced nausea and vomiting. Anesthesia and Analgesia. 1997;84(4):832–838. | 2
Seynaeve C, Schuller J, Buser K, et al. Comparison of the anti-emetic efficacy of different doses of ondansetron, given as either a continuous infusion or a single intravenous dose, in acute cisplatin-induced emesis. A multicentre, double-blind, randomised, parallel group study. British Journal of Cancer. 1992;66(1):192–197. | 2
Spitzer TR, Bryson JC, Cirenza E, et al. A randomized, double-blind, placebo-controlled trial of ondansetron (OND) in the prevention of total body irradiation (TBI) induced emesis. Blood. 1993;82(10 Suppl 1):419a. | 5
Spitzer TR, Bryson JC, Cirenza E, et al. Randomized double-blind, placebo-controlled evaluation of oral ondansetron in the prevention of nausea and vomiting associated with fractionated total-body irradiation. Journal of Clinical Oncology. 1994;12(11):2432–2438. | 6
Suminaga M, Furue H, Ohta K, Taguchi T, Niitani H, Ogawa N. Clinical evaluation of granisetron for nausea and vomiting induced by anticancer drugs - Multi centered placebo controlled double-blind comparative study. Japanese Journal of Cancer and Chemotherapy. 1993;20(9):1211–1219. | 2
Tiley C, Powles R, Catalano J, et al. Results of a double blind placebo controlled study of ondansetron as an antiemetic during total body irradiation in patients undergoing bone marrow transplantation. Leukemia and Lymphoma. 1992;7(4):317–321. | 6
Triem JG, Piper SN, Maleck WH, Schenck A, Schmidt CC, Boldt J. Prevention of postoperative nausea and vomiting (PONV) with single oral dose of dolasetron, compared to single dose of intravenous droperidol and a combination of both substances in patients undergoing hysterectomy. Objective. Anasthesiologie, Intensivmedizin, Notfallmedizin, Schmerztherapie. 1999;34(6):340–344. | 1
Uchida K, Akaza H, Hattori K, et al. Antiemetic efficacy of granisetron: a randomized crossover study in patients receiving cisplatin-containing intraarterial chemotherapy. Japanese Journal of Clinical Oncology. 1999;29(2):87–91. | 2
Watcha MF, Bras PJ, Cieslak GD, Pennant JH. The dose-response relationship of ondansetron in preventing postoperative emesis in pediatric patients undergoing ambulatory surgery. Anesthesiology. 1995;82(1):47–52. | 2
Yuksek MS, Alici HA, Erdem AF, Cesur M. Comparison of prophylactic anti-emetic effects of ondansetron and dexamethasone in women undergoing day-case gynaecological laparoscopic surgery. Journal of International Medical Research. 2003;31(6):481–488. | 2