# Methods to assess quality of studies

Study quality was objectively assessed using predetermined criteria for internal validity, which were based on a combination of the US Preventive Services Task Force and the National Health Service Centre for Reviews and Dissemination1, 2 criteria.

All included studies, regardless of design, were assessed for quality and assigned a rating of “good,” “fair,” or “poor”. Studies that have a fatal flaw were rated poor quality. A fatal flaw was the failure to meet combinations of criteria that may be related to indicate the presence of bias. An example would be inadequate procedures for allocation concealment combined with important differences between groups in prognostic factors at baseline and following randomization. Studies that meet all criteria were rated good quality; the remainder were rated fair quality. As the fair-quality category was broad, studies with this rating varied in their strengths and weaknesses: The results of some fair-quality studies were likely to be valid, while others were only possibly valid. A poor-quality trial was not valid; the results were at least as likely to reflect flaws in the study design as a true difference between the compared drugs.

## Systematic Reviews

1. Does the systematic review report a clear review question and clearly state inclusion and exclusion criteria for primary studies?
  A good-quality review focuses on a well-defined question or set of questions, which ideally refer to the inclusion/exclusion criteria by which decisions are made about whether to include or exclude primary studies. These criteria would relate to the four components of study design, indications (patient populations), interventions (drugs), and outcomes of interest. A good-quality review also includes details about the process of decision-making, that is, how many reviewers were involved, whether the studies were examined independently, and how disagreements between reviewers were resolved.
2. Is there evidence of a substantial effort to find all relevant research?
  If details of electronic database searches and other identification strategies are given, the answer to this question usually is yes. Ideally, search terms, date restrictions, and language restrictions are presented. In addition, descriptions of hand-searches, attempts to identify unpublished material, and any contact with authors, industry, or research institutes should be provided. The appropriateness of the database(s) searched by the authors should also be considered. For example, if only MEDLINE is searched for a systematic review about health education, then it is unlikely that all relevant studies will be located.
3. Is the validity of included studies adequately assessed?
  If the review systematically assesses the quality of primary studies, it should include an explanation of the basis for determining quality (for example, method of randomization, whether outcome assessment was blinded, whether analysis was on an intention-to-treat basis) and the process by which assessment is carried out (that is, how many reviewers are involved, whether the assessment is independent, and how discrepancies between reviewers are resolved). Authors may have used either a published checklist or scale or one that they designed specifically for their review.
4. Is sufficient detail of the individual studies presented?
  The review should show that the included studies are suitable to answer the question posed and that a judgment on the appropriateness of the authors’ conclusions can be made. It is usually considered sufficient if a paper includes a table giving information on the design and results of individual studies or includes a narrative description of the studies. If relevant, the tables or text should include information on study design, sample size for each study group, patient characteristics, interventions, settings, outcome measures, follow-up, drop-out rate (withdrawals), effectiveness results, and adverse events.
5. Are the primary studies summarized appropriately?
  The authors should attempt to synthesize the results from individual studies. In all cases, there should be a narrative summary of results, which may or may not be accompanied by a quantitative summary (meta-analysis).
  For reviews that use a meta-analysis, heterogeneity between studies should be assessed using statistical techniques. If heterogeneity is present, the possible reasons (including chance) should be investigated. In addition, the individual evaluations should be weighted in some way (for example, according to sample size or according to inverse of the variance) so that studies that are thought to provide the most reliable data have greater impact on the summary statistic.

## Controlled Trials

### Assessment of Internal Validity

1. Was the assignment to the treatment groups really random?
- Yes | Use of the term “randomized” alone is not sufficient for a judgment of “Yes”. Explicit description of method for sequence generation must be provided. Adequate approaches include: Computer-generated random numbers, random numbers tables
- No | Randomization was either not attempted or was based on an inferior approach (e.g., alternation, case record number, birth date, or day of week)
- Unclear | Insufficient detail provided to make a judgment of yes or no.
2. Was the treatment allocation concealed?
- Yes | Adequate approaches to concealment of randomization: Centralized or pharmacy-controlled randomization, serially-numbered identical containers, on-site computer based system with a randomization sequence that is not readable until allocation Note: If a trial did not use adequate allocation concealment methods, the highest rating it can receive is “Fair”.
- No | Inferior approaches to concealment of randomization: Use of alternation, case record number, birth date, or day of week, open random numbers lists, serially numbered envelopes (even sealed opaque envelopes can be subject to manipulation)
- Unclear | No details about allocation methods. A statement that “allocation was concealed” is not sufficient; details must be provided.
3. Were groups similar at baseline in terms of prognostic factors?
- Yes | Parallel design: No clinically important differences Crossover design: Comparison of baseline characteristics must be made based on order of randomization. Note: Determine beforehand which prognostic factors are important to consider. A statistically significant difference does not automatically constitute a clinically important difference.
- No | Parallel design: Clinically important differences Crossover design: Only reported baseline characteristics of the overall group.
- Unclear | Statement of “no differences at baseline”, but data not reported; or data not reported by group, or no mention at all of baseline characteristics
4. Were eligibility criteria specified?
- Yes | Eligibility criteria were specified a priori.
- No | Criteria not reported or description of enrolled patients only.
5. Were outcome assessors blinded to treatment allocation? 6. Was the care provider blinded? 7. Was the patient blinded?
- Yes | Explicit statement(s) that outcome assessors/care provider/patient were blinded. Double-dummy studies and use of identically-appearing treatments are also considered sufficient blinding methods for patients and care providers.
- No | No blinding used, open-label
- Unclear, described as double-blind | Study described as double-blind but no details provided.
- Not reported | No information about blinding
8. Did the article include an intention-to-treat analysis or provide the data needed to calculate it (that is, number assigned to each group, number of subjects who finished in each group, and their results)?
- Yes | All patients that were randomized were included in the analysis. Specify if imputation methods (e.g., last-observation carried forward) were used. OR Exclusion of 5% of patients or less is acceptable, given that the reasons for exclusion are not related to outcome (e.g., did not take study medication) and that the exclusions would not be expected to have an important impact on the effect size
- No | Exclusion of greater than 5% of patients from analysis OR less than 5%, with reasons that may affect the outcome (e.g., adverse events, lack of efficacy) or reasons that may be due to bias (e.g., investigator decision)
- Unclear | Numbers analyzed are not reported
9. Did the study maintain comparable groups?
- Yes | No attrition. OR, the groups analyzed remained similar in terms of their baseline prognostic factors.
- No | Groups analyzed had clinically important differences in important baseline prognostic factors
- Unclear | There was attrition, but insufficient information to determine if groups analyzed had clinically important differences in important baseline prognostic factors
10. Were levels of crossovers (≤ 5%), adherence (≤ 20%), and contamination (≤ 5%) acceptable?
- Yes | Levels of crossovers, adherence and contamination were below specified cut-offs.
- No | Levels or crossovers, adherence, and contamination were above specified cut-offs.
- Unclear | Insufficient information provided to determine the level of crossovers, adherence and contamination.
11. Was the rate of overall attrition and the difference between groups in attrition within acceptable levels?
Overall attrition: There is no empirical evidence to support establishment of a specific level of attrition that is universally considered “important”. The level of attrition considered important will vary by review and should be determined a priori by the review teams. Attrition refers to discontinuation for ANY reason, including lost to follow-up, lack of efficacy, adverse events, investigator decision, protocol violation, consent withdrawal, etc.
- Yes | The overall attrition rate was below the level that was established by the review team.
- No | The overall attrition rate was above the level that was established by the review team.
- Unclear | Insufficient information provided to determine the level of attrition
Differential attrition
- Yes | The absolute difference between groups in rate of attrition was below 10%.
- No | The difference between groups in the overall attrition rate or in the rate of attrition for a specific reason (e.g., adverse events, protocol violations, etc.) was 10% or more.
- Unclear | Insufficient information provided to determine the level of attrition

Note: For any “no” response, provide an explanation; e,g., describe inadequate allocation concealment methods

## Nonrandomized studies

### Assessment of Internal Validity

1. Was the selection of patients for inclusion unbiased? (Was any group of patients systematically excluded?)
2. Was there important differential loss to follow-up or overall high loss to follow-up? (Numbers should be given for each group.)
3. Were the events investigated specified and defined?
4. Was there a clear description of the techniques used to identify the events?
5. Was there unbiased and accurate ascertainment of events (that is, by independent ascertainers using a validated ascertainment technique)?
6. Were potential confounding variables and risk factors identified and examined using acceptable statistical techniques?
7. Was the duration of follow-up reasonable for investigated events?

## References

1 Center for Reviews and Dissemination, University of York. 2001. Undertaking systematic reviews of research on effectiveness: CRD’s guidance for those carrying out or commissioning reviews. CRD ReportNumber 4(2nd edition).
2 Harris RP, Helfand M, Woolf SH. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3 Suppl):21-35. [pmid: 11306229].