# Search strategies

Database: Ovid MEDLINE(R) <1996 to September Week 4 2009>

Search Strategy:

1. aprepitant.mp. (238)
2. dolasetron.mp. (210)
3. granisetron.mp. or Granisetron/ (771)
4. ondansetron.mp. or Ondansetron/ (1892)
5. palonosetron.mp. (113)
6. 1 or 2 or 3 or 4 or 5 (2723)
7. limit 6 to (english language and humans) (1802)
8. (20081$ or 2009$).ed. (688349)
9. 8 and 7 (147)
10. chemotherapy.mp. (128292)
11. Radiation/ (881)
12. 11 or 10 (129166)
13. 9 and 12 (43)
14. from 13 keep 1–43 (43)

Database: Ovid MEDLINE(R) <1996 to September Week 4 2009>

Search Strategy:

1. aprepitant.mp. (238)
2. dolasetron.mp. (210)
3. granisetron.mp. or Granisetron/ (771)
4. ondansetron.mp. or Ondansetron/ (1892)
5. palonosetron.mp. (113)
6. 1 or 2 or 3 or 4 or 5 (2723)
7. limit 6 to (english language and humans) (1802)
8. exp Radiotherapy/ (54169)
9. exp Neoplasms/ (920446)
10. exp Antineoplastic Agents/ (323717)
11. 8 or 10 or 9 (1104504)
12. 11 and 7 (684)
13. (20081$ or 2009$).ed. (688349)
14. 13 and 12 (54)
15. exp Nausea/pc, dt [Prevention & Control, Drug Therapy] (2827)
16. exp Vomiting/dt [Drug Therapy] (1093)
17. (nausea$ or emesis or emetic$ or antiemet$ or anti-emet$ or vomit$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (33308)
18. 16 or 17 or 15 (33342)
19. 18 and 7 (1393)
20. 19 and 13 (111)
21. 20 not 14 (59)
22. from 14 keep 1–54 (54)

Database: Ovid MEDLINE(R) <1996 to September Week 4 2009>

Search Strategy:

1. aprepitant.mp. (238)
2. dolasetron.mp. (210)
3. granisetron.mp. or Granisetron/ (771)
4. ondansetron.mp. or Ondansetron/ (1892)
5. palonosetron.mp. (113)
6. 1 or 2 or 3 or 4 or 5 (2723)
7. limit 6 to (english language and humans) (1802)
8. exp Radiotherapy/ (54169)
9. exp Neoplasms/ (920446)
10. exp Antineoplastic Agents/ (323717)
11. 8 or 10 or 9 (1104504)
12. 11 and 7 (684)
13. (20081$ or 2009$).ed. (688349)
14. 13 and 12 (54)
15. exp Nausea/pc, dt [Prevention & Control, Drug Therapy] (2827)
16. exp Vomiting/dt [Drug Therapy] (1093)
17. (nausea$ or emesis or emetic$ or antiemet$ or anti-emet$ or vomit$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (33308)
18. 16 or 17 or 15 (33342)
19. 18 and 7 (1393)
20. 19 and 13 (111)
21. 20 not 14 (59)
22. from 21 keep 1–59 (59)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3rd Quarter 2009>

Search Strategy:

1. aprepitant.mp. (44)
2. dolasetron.mp. (141)
3. granisetron.mp. or Granisetron/ (526)
4. ondansetron.mp. or Ondansetron/ (1332)
5. palonosetron.mp. (25)
6. 1 or 2 or 3 or 4 or 5 (1865)
7. chemotherapy.mp. (21556)
8. Radiation/ (22)
9. 8 or 7 (21578)
10. 6 and 9 (674)
11. limit 10 to yr=“2008 – 2009” (11)
12. from 11 keep 1–11 (11)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <3rd Quarter 2009>

Search Strategy:

1. aprepitant.mp. (2)
2. dolasetron.mp. (6)
3. granisetron.mp. or Granisetron/ (11)
4. ondansetron.mp. or Ondansetron/ (22)
5. palonosetron.mp. (3)
6. 1 or 2 or 3 or 4 or 5 (23)
7. chemotherapy.mp. [mp=title, short title, abstract, full text, keywords, caption text] (510)
8. radiation.mp. [mp=title, short title, abstract, full text, keywords, caption text] (269)
9. 8 or 7 (630)
10. 6 and 9 (9)
11. from 10 keep 1–9 (9)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects <3rd Quarter 2009>

Search Strategy:

1. aprepitant.mp. (0)
2. dolasetron.mp. (4)
3. granisetron.mp. or Granisetron/ (12)
4. ondansetron.mp. or Ondansetron/ (33)
5. palonosetron.mp. (0)
6. 1 or 2 or 3 or 4 or 5 (34)
7. chemotherapy.mp. [mp=title, full text, keywords] (520)
8. radiation.mp. [mp=title, full text, keywords] (177)
9. 8 or 7 (637)
10. 6 and 9 (10)
11. from 10 keep 1–10 (10)

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1948 to January Week 3 2010>

Search Strategy:

1. (prescri$ adj5 pattern$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (2307)
2. ondansetron.mp. or exp Ondansetron/ (2965)
3. 1 and 2 (4)
4. (prescri$ adj7 pattern$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (2472)
5. (prescri$ adj7 utiliz$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (3529)
6. (prescri$ adj7 trend$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (682)
7. (prescri$ adj7 us$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (12253)
8. 4 or 5 or 6 or 7 (16524)
9. aprepitant.mp. (246)
10. dolasetron.mp. (234)
11. granisetron.mp. or Granisetron/ (1162)
12. ondansetron.mp. or exp Ondansetron/ (2965)
13. palonosetron.mp. (119)
14. antiemetic.mp. or exp Antiemetics/ (116294)
15. 9 or 10 or 11 or 12 or 13 or 14 (117071)
16. 8 and 15 (161)
17. chemotherapy.mp. (218333)
18. exp Neoplasms/ or exp Antineoplastic Agents/ or chemo$.mp. or exp Antineoplastic Combined Chemotherapy Protocols/ (2598444)
19. radiation.mp. or exp Radiation/ (455654)
20. radiotherapy.mp. or exp Radiotherapy/ (159878)
21. cancer.mp. (703421)
22. 17 or 18 or 19 or 20 or 21 (3001445)
23. 16 and 22 (38)
24. from 23 keep 1–38 (38)

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1948 to January Week 1 2010>

Search Strategy:

1. aprepitant.mp. (245)
2. dolasetron.mp. (234)
3. granisetron.mp. (1162)
4. ondansetron.mp. (2961)
5. palonosetron.mp. (117)
6. 1 or 2 or 3 or 4 or 5 (4064)
7. exp Physician’s Practice Patterns/ (28867)
8. exp Decision Making/ (86852)
9. exp Socioeconomic Factors/ (263621)
10. exp “Attitude of Health Personnel”/ (94635)
11. exp Drug Prescriptions/ (18574)
12. exp Drug Utilization/ (16012)
13. exp Health Services Accessibility/ (64229)
14. exp decision support techniques/ (42792)
15. 6 and 7 (9)
16. 6 and 8 (5)
17. 6 and 9 (1)
18. 6 and 10 (8)
19. 6 and 11 (5)
20. 6 and 12 (22)
21. 6 and 13 (1)
22. 6 and 14 (14)
23. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 (56)
24. exp Vomiting/dt [Drug Therapy] (2199)
25. Antiemetics/ad, ae, ct, tu, ec, sd (4798)
26. 24 or 25 (5832)
27. 7 and 26 (37)
28. 8 and 26 (13)
29. 9 and 26 (11)
30. 10 and 26 (36)
31. 11 and 26 (21)
32. 12 and 26 (32)
33. 13 and 26 (3)
34. 14 and 26 (24)
35. 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 (159)
36. exp Neoplasms/ (2099634)
37. exp Radiotherapy/ (110944)
38. rt.fs. (132454)
39. exp Antineoplastic Agents/ (663990)
40. 36 or 37 or 38 or 39 (2507794)
41. 35 and 40 (64)
42. 23 or 41 (104)
43. limit 42 to english language (98)
44. from 43 keep 1–98 (98)

Database: Ovid MEDLINE(R) <1996 to January Week 1 2010>

Search Strategy:

1. aprepitant.mp. (245)
2. dolasetron.mp. (212)
3. granisetron.mp. or Granisetron/ (782)
4. ondansetron.mp. or exp Ondansetron/ (1915)
5. palonosetron.mp. (114)
6. 1 or 2 or 3 or 4 or 5 (2762)
7. Drug Utilization.mp. or exp Drug Utilization/ (10618)
8. Drug Prescriptions/ or Physician’s Practice Patterns/ (34094)
9. Health services needs.mp. or exp “Health Services Needs and Demand”/ (24224)
10. 7 or 8 or 9 (64558)
11. 6 and 10 (18)
12. from 11 keep 1–18 (18)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <4th Quarter 2009>

Search Strategy:

1. aprepitant.mp. (45)
2. dolasetron.mp. (142)
3. granisetron.mp. or exp Granisetron/ (532)
4. ondansetron.mp. or exp Ondansetron/ (1318)
5. palonosetron.mp. (26)
6. antiemetics.mp. or exp Antiemetics/ (12012)
7. 1 or 2 or 3 or 4 or 5 or 6 (12736)
8. physician’s practice patterns.mp. or exp Physician’s Practice Patterns/ (633)
9. Prescribing.mp. (1038)
10. decision making.mp. or exp Decision Making/ (2296)
11. exp Socioeconomic Factors/ (3833)
12. attitude of health personnel.mp. or exp “Attitude of Health Personnel”/ (1112)
13. Drug Prescriptions.mp. or exp Prescriptions, Drug/ (279)
14. Drug Utilization.mp. or exp Drug Utilization/ (387)
15. Health Services Accessibility.mp. or exp Health Services Accessibility/ (390)
16. exp Decision Support Systems, Clinical/ or exp Decision Support Techniques/ (1533)
17. 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 (10241)
18. 7 and 17 (128)
19. neoplasms.mp. or exp Neoplasms/ (32300)
20. radiotherapy.mp. or exp Radiotherapy/ (8448)
21. rt.fs. (5493)
22. antineoplastic agents.mp. or exp Antineoplastic Agents/ (28005)
23. 19 or 20 or 21 or 22 (49611)
24. 18 and 23 (25)
25. from 24 keep 1–25 (25)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <1st Quarter 2010>

Search Strategy:

1. aprepitant.mp. (46)
2. dolasetron.mp. (145)
3. granisetron.mp. (538)
4. ondansetron.mp. (1382)
5. palonosetron.mp. (27)
6. 1 or 2 or 3 or 4 or 5 (1927)
7. prescri$.mp. (6829)
8. ((decis$ adj3 (make or making or made)) or deciding or decide$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (3165)
9. socioecon$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (1892)
10. ((social$ or educat$) adj3 (class$ or status or standing or achiev$ or level$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (2864)
11. (poverty or indigen$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (912)
12. ((care or therap$ or treat$) adj5 (access or ration or rationing or rationed or inacces$ or deny or denied or denial$ or denying)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (729)
13. ((doctor$ or physician$ or specialist$ or oncologist$ or practice) adj5 (attitud$ or opinion$ or prefer$ or recommend$)).mp. (3485)
14. 7 or 8 or 9 or 10 or 11 or 12 or 13 (18111)
15. 6 and 14 (21)
16. (cancer$ or tumor$ or tumour$ or maligna$ or carcino$ or metasta$ or neoplas$ or radiother$ or chemother$ or radiation therap$).mp. (62839)
17. (anti-emetic$ or anti-nausea$ or antiemetic$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (2906)
18. 14 and 16 and 17 (21)
19. 15 or 18 (35)
20. from 19 keep 1–35 (35)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <4th Quarter 2009>

Search Strategy:

1. aprepitant.mp. (2)
2. dolasetron.mp. (6)
3. granisetron.mp. (11)
4. ondansetron.mp. (22)
5. palonosetron.mp. (3)
6. 1 or 2 or 3 or 4 or 5 (23)
7. prescri$.mp. (1431)
8. ((decis$ adj3 (make or making or made)) or deciding or decide$).mp. [mp=title, abstract, full text, keywords, caption text] (1788)
9. socioecon$.mp. [mp=title, abstract, full text, keywords, caption text] (215)
10. ((social$ or educat$) adj3 (class$ or status or standing or achiev$ or level$)).mp. [mp=title, abstract, full text, keywords, caption text] (341)
11. (poverty or indigen$).mp. [mp=title, abstract, full text, keywords, caption text] (139)
12. ((care or therap$ or treat$) adj5 (access or ration or rationing or rationed or inacces$ or deny or denied or denial$ or denying)).mp. [mp=title, abstract, full text, keywords, caption text] (295)
13. ((doctor$ or physician$ or specialist$ or oncologist$ or practice) adj5 (attitud$ or opinion$ or prefer$ or recommend$)).mp. (593)
14. 7 or 8 or 9 or 10 or 11 or 12 or 13 (3243)
15. 6 and 14 (14)
16. (cancer$ or tumor$ or tumour$ or maligna$ or carcino$ or metasta$ or neoplas$ or radiother$ or chemother$ or radiation therap$).mp. (1894)
17. (anti-emetic$ or anti-nausea$ or antiemetic$).mp. [mp=title, abstract, full text, keywords, caption text] (65)
18. 14 and 16 and 17 (26)
19. 15 or 18 (34)
20. from 19 keep 1–34 (34)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <4th Quarter 2009>

Search Strategy:

1. aprepitant.mp. (2)
2. dolasetron.mp. (6)
3. granisetron.mp. or exp Granisetron/ (11)
4. ondansetron.mp. or exp Ondansetron/ (22)
5. palonosetron.mp. (3)
6. antiemetics.mp. or exp Antiemetics/ (36)
7. 1 or 2 or 3 or 4 or 5 or 6 (49)
8. physician’s practice patterns.mp. or exp Physician’s Practice Patterns/ (23)
9. Prescribing.mp. (306)
10. decision making.mp. or exp Decision Making/ (360)
11. attitude of health personnel.mp. or exp “Attitude of Health Personnel”/ (6)
12. Drug Prescriptions.mp. or exp Prescriptions, Drug/ (5)
13. Drug Utilization.mp. or exp Drug Utilization/ (5)
14. Health Services Accessibility.mp. or exp Health Services Accessibility/ (8)
15. socioeconomic.mp. [mp=title, short title, abstract, full text, keywords, caption text] (212)
16. decision support.mp. [mp=title, short title, abstract, full text, keywords, caption text] (36)
17. 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 (831)
18. 7 and 17 (3)
19. from 18 keep 1–3 (3)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects <4th Quarter 2009>

Search Strategy:

1. aprepitant.mp. (0)
2. dolasetron.mp. (6)
3. granisetron.mp. (14)
4. ondansetron.mp. (36)
5. palonosetron.mp. (0)
6. 1 or 2 or 3 or 4 or 5 (37)
7. prescri$.mp. (339)
8. ((decis$ adj3 (make or making or made)) or deciding or decide$).mp. [mp=title, full text, keywords] (353)
9. socioecon$.mp. [mp=title, full text, keywords] (96)
10. ((social$ or educat$) adj3 (class$ or status or standing or achiev$ or level$)).mp. [mp=title, full text, keywords] (129)
11. (poverty or indigen$).mp. [mp=title, full text, keywords] (20)
12. ((care or therap$ or treat$) adj5 (access or ration or rationing or rationed or inacces$ or deny or denied or denial$ or denying)).mp. [mp=title, full text, keywords] (60)
13. ((doctor$ or physician$ or specialist$ or oncologist$ or practice) adj5 (attitud$ or opinion$ or prefer$ or recommend$)).mp. (526)
14. 7 or 8 or 9 or 10 or 11 or 12 or 13 (1359)
15. 6 and 14 (6)
16. (cancer$ or tumor$ or tumour$ or maligna$ or carcino$ or metasta$ or neoplas$ or radiother$ or chemother$ or radiation therap$).mp. (1950)
17. (anti-emetic$ or anti-nausea$ or antiemetic$).mp. [mp=title, full text, keywords] (73)
18. 14 and 16 and 17 (4)
19. 15 or 18 (8)
20. from 19 keep 1–8 (8)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects <4th Quarter 2009>

Search Strategy:

1. aprepitant.mp. (0)
2. dolasetron.mp. (6)
3. granisetron.mp. or exp Granisetron/ (14)
4. ondansetron.mp. or exp Ondansetron/ (36)
5. palonosetron.mp. (0)
6. antiemetics.mp. or exp Antiemetics/ (59)
7. 1 or 2 or 3 or 4 or 5 or 6 (67)
8. physician’s practice patterns.mp. or exp Physician’s Practice Patterns/ (53)
9. Prescribing.mp. (96)
10. decision making.mp. or exp Decision Making/ (160)
11. attitude of health personnel.mp. or exp “Attitude of Health Personnel”/ (20)
12. Drug Prescriptions.mp. or exp Prescriptions, Drug/ (18)
13. Drug Utilization.mp. or exp Drug Utilization/ (19)
14. Health Services Accessibility.mp. or exp Health Services Accessibility/ (32)
15. socioeconomic.mp. [mp=title, full text, keywords] (94)
16. decision support.mp. [mp=title, full text, keywords] (57)
17. 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 (474)
18. 7 and 17 (1)
19. from 18 keep 1 (1)