# US Food and Drug Administration recommendations for adult dosages

I Dosages for prevention of emesis associated with chemotherapy^a,b^

Drug (brand name) | Form | Emetic risk
Drug (brand name) | Form | Moderate | High
Aprepitant (Emend^®^) | Capsule | 125 mg once on day 1 then 80 mg once daily on days 2 to 3 | 125 mg once on day 1 then 80 mg once daily on days 2 to 3
Fosaprepitant (Emend^®^) | Injection | 115 mg IV once on day 1 then 80 mg orally once daily on days 2 to 3 | 115 mg IV once on day 1 then 80 mg orally once daily on days 2 to 3
5-HT3 antagonists
Dolasetron (Anzemet^®^) | Injection | 1.8 mg/kg or 100 mg once | 1.8 mg/kg or 100 mg once
Dolasetron (Anzemet^®^) | Tablet | 100 mg once | Not established
Granisetron (Kytril^®^) | Injection | 10 mcg/kg once | 10 mcg/kg once
Granisetron (Kytril^®^) | Tablet, oral solution | 2 mg once or 1 mg BID | 2 mg once or 1 mg BID
Ondansetron (Zofran^®^) | Injection | 32 mg once or 0.15 mg/kg TID | 32 mg once
Ondansetron (Zofran^®^) | Tablet, orally disintegrating tablet, oral solution | 8 mg BID on Days 1 to 3 | 24 mg once
Palonosetron (Aloxi^®^) | Injection | 0.25 mg once | 0.25 mg once
Palonosetron (Aloxi^®^) | Tablet | 0.5 mg once | Not established

Abbreviations: BID, twice daily; IV, intravenous; TID, three times daily.

a This table does not attempt to address any recommendations regarding the use of NK-1 and 5-HT3 antagonists in combination with other agents, such as steroids.

b Dosages are for day 1 administered once, prior to chemotherapy, unless otherwise noted.

II Dosages for prevention of emesis following radiotherapy

Drug (brand name) | Form | Dosage^a^
Granisetron (Kytril^®^) | Injection | Not established
Granisetron (Kytril^®^) | Tablet, oral solution | 2 mg once
Ondansetron (Zofran^®^) | Injection | Not established
Ondansetron (Zofran^®^) | Tablet, orally disintegrating tablet, oral solution | 8 mg three times daily

a Administered prior to radiotherapy, unless otherwise specified.