# ABBREVIATIONS USED IN THE REPORT

Abbreviation: Term
5-HT3: 5-hydroxytryptamine-3
AHRQ: Agency for Healthcare Research and Quality
bid: Twice daily
CI: Confidence interval
CMS: Centers for Medicare and Medicaid Services
DERP: Drug Effectiveness Review Project
FDA: US Food and Drug Administration
FLIE: Functional Living Index-Emesis questionnaire
IV: Intravenous
N: Number/population
NK1: P/neurokinin 1
NR: Not reported
Oregon EPC: Oregon Evidence-based Practice Center
PO: Palonosetron
qd: Once daily
RR: Relative risk
TAP: The Technology Assessment Program