# Results

## Literature Search

We included 112 publications reporting on the tests of interest (Figure 3). We included 21 publications for Key Question (KQ) 2, 70 for KQ 3, and 22 for KQ 4a. We found no eligible studies for KQ 1, KQ 4b, or KQ 5. Of the included studies, we rated 31 as low, 57 as medium, 12 as high, and 12 as unclear risk of bias (RoB).

Figure 3 Disposition of articles

Figure 3 is a PRISMA tree that documents the disposition of publications reviewed for this review. There were 4,212 citations identified from searches across the databases of PubMed, EMBASE, and Cochrane. Additionally, 1,065 publications were detected from manufacturers' clinical trials, manufacturers' published articles, manufacturers' unpublished documents and manufacturers' conference proceedings, clinical trials.gov website, HSR Proj Trials database, and hand searches. Of the total 3,340 abstracts screened, 1,693 citations were excluded. Working from 1,647 articles retrieved for full review, 1,551 were excluded at this stage. Of the studies excluded at the full review 8 were excluded for a systematic review, 93 were excluded for wrong publication type, 208 were excluded for wrong population, 498 were excluded for wrong intervention, 153 were excluded for wrong or no comparator, 494 were excluded for wrong or no outcome, 76 were excluded for wrong study design, 18 were excluded for not applying to a key question, and 3 were excluded for not being able to retrieve the full-text article. The review included 96 publications.

## Results of Included Studies

### Key Question 1 Direct Evidence That Using the Tests Changes Physician Decisionmaking and Improves Outcomes

We found no eligible studies that addressed this overarching question.

### Key Question 2 Analytic Validity

We included 21 studies, using a total of 23 different tests (Table 5) as well as data from the College of American Pathologists. We analyzed marker test performance and intra/interlab reproducibility.

Table 5 Characteristics of included studies reporting on analytic validity, by test and cancer

Author, Year, Design, Test (Primary Site), Risk of Bias | Vendor, Developer of Test | Tissue Sample Requirements, Type of Analyte, Measure Technique | Neoplasms, Lab Reporting Results, Test Measure, Tissues in Sample
Abbot Labs, 2011^32^ Validation ALK (lung) Unclear | Abbot Labs Vendor | FFPE DNA fluorescence in situ hybridization (FISH) | Nonsmall cell lung cancer Authors’ lab(s) Chromosome rearrangements 136
Angulo, 2013^33^ Test-retest EGFR (lung) Low | Qiagen Vendor | FFPE DNA PCR followed by therascreen® EGFR Mutation Kit | Nonsmall cell lung cancer Histology: Carcinomas NOS (23.5%) Squamous cell carcinomas (10.3%) Adenocarcinomas (64%) Large cell carcinomas (2.2%) Authors’ lab(s) EGFR mutations at exons 19 to 21 136
Bando, 2010^34^ Validation KRAS (colorectal) Medium | DxS Ltd.; Vienna Lab Diagnostics, Vendor | FFPE DNA Direct (Sanger) sequencing; therascreen KRAS Mutation Kit: Allele-specific PCR with Scorpion fluorescent probes (ARMS/S); KRAS Strip-Assay: Reverse hybridization (RH) | CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 100
Beau-Faller, 2011^35^ Validation EGFR (lung) Low | NA Lab developed for each center | FFPE and frozen DNA Direct or nested sequencing; each center used their own standard procedure. | Nonsmall cell lung cancer NR EGFR mutations at exons 18 to 21 74
Beau-Faller, 2009^36^ Test-retest KRAS (lung) Low | Roche (Germany), Eurogentec (Belgium), Timolbiol (Germany); Lab developed | Frozen DNA PNA-mediated PCR clamping | Nonsmall cell lung cancer Authors’ lab(s) KRAS mutations at codons 12 and 13 114
Beau-Faller, 2011^35^ Validation KRAS (lung) Low | NA Lab developed for each center | FFPE and frozen DNA Direct or nested sequencing; each center used their own standard procedure. | Nonsmall cell lung cancer NR KRAS mutations at exon 2 74
Clark-Langone 2010^37^ Test-retest Oncotype DX (colorectal) Medium | Genomic Health Vendor | FFPE RNA RT-PCR of 12-gene Recurrence Score Assay | Stage II adenocarcinoma and mucinous carcinoma Authors’ lab(s) Expression levels NR
Cronin, 2007^38^ Test-retest Oncotype Dx (Breast) Unclear | Genomic Health Vendor | FFPE RNA RT-PCR of 21-gene Recurrence Score Assay | Node-negative, estrogen receptor–positive breast cancer Vendor’s lab Expression levels NR
Delahaye, 2013^39^ Test-retest MammaPrint (breast) Medium | Agendia NV, Amsterdam, The Netherlands Vendor | Fresh tissue RNA Microarray | Early-stage, invasive breast cancer Vendor’s labs Expression levels N = 100 (cross lab validity tests)
Feigelson, 2012^40^ KRAS (colorectal) Low | NA Lab developed for each center | FFPE DNA PCR amplification followed by Direct Sanger sequencing, PCR amplification followed by standard bidirectional sequencing, PCR amplification followed by sequencing, Single nucleotide primer extension with fragment analysis by capillary electrophoresis using a modified SNaPshot assay, or Qualitative real time PCR. | CRC (18 adenocarcinoma, 2 carcinoma) Genzyme, Clarient, Quest Diagnostics, Henry Ford Health System & Molecular and Medical Genetics-Oregon Health and Science University KRAS mutations at codons 12 and 13 20
Gao, 2010^41^ Validation KRAS (colorectal) Unclear | Vienna Lab of Austria CND | FFPE DNA Dideoxy sequencing, KRAS StripAssay and pyrosequencing | CRC Authors’ lab(s) KRAS mutation s at exon 2 NR
Gonzalez de Castro 2012^42^ Test-retest KRAS (colorectal) Low | Roche Molecular Systems, Inc., Qiagen Vendor | FFPE DNA Cobas EGFR Mutation Test (AS-PCR) therascreen EGFR29 Mutation Kit (ARMS); 2× bidirectional; Sanger sequencing | CRC 2 clinical site labs KRAS mutations at codons 12 and 13 115
Hancer, 2011^43^ Cohort KRAS (colorectal) Unclear | 1) Big Dye Terminator kit v.3.1 (Applied Biosystems, Foster City, CA); 2) DxS Ltd., Manchester, United Kingdom; 3) Entrogen, Tarzana, CA Vendor | FFPE DNA Dideoxy sequencing, therascreen KRAS kit, and Entrogen KRAS mutation analysis kit | Adenocarcinomas of the colon and the rectum Authors’ lab(s) KRAS mutations at codons 12 and 13 64
Jancik, 2012^44^ Test-retest KRAS (lung) High | PyroMark KRAS assay test: Biotage, Uppsala, Sweden therascreen DxS KRAS Mutation Kits KR-21 and KR-22: QiaGen, Hilden, Germany KRAS StripAssay REF 5–590: ViennaLab Diagnostics GmbH, Vienna, Austria Direct sequencing and HRM analysis used components from various vendors Vendor | Frozen DNA Direct sequencing, Pyrosequencing, therascreen DxS, KRAS StripAssay kits, and HRM analysis | Nonsmall cell lung cancer Authors’ lab(s) KRAS mutations at codons 12 and 13 131
Kobunai, 2010^45^ Test-retest KRAS (colorectal) Low | Qiagen, Panagene Lab developed | Frozen DNA Peptide nucleic acid (PNA)-clamp real-time PCR | CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 224
Lopez-Rios 2013^46^ Test-retest EGFR (lung) Low | Roche Molecular Systems, Inc., Qiagen, Vendor | FFPE DNA Cobas EGFR Mutation Test (AS-PCR) therascreen EGFR29 Mutation Kit (ARMS); 2× bidirectional; Sanger sequencing | Nonsmall cell lung cancer 2 clinical site labs EGFR mutations at exons 18 to 21 124
Mancini, 2010^47^ Test-retest BRAF (colorectal) Medium | NA Lab developed | Frozen DNA PCR: Cold PCR—sensitivity then evaluated by high-resolution melting (HRM) analysis and sequencing | Sporadic colorectal cancer (CRC) Authors’ lab(s) BRAF mutations at exon 15 117
Mancini, 2010^47^ Test-retest KRAS (colorectal) Medium | NA Lab developed | Frozen DNA PCR: Cold PCR—sensitivity then evaluated by HRM analysis and sequencing | Sporadic CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 117
Naoki, 2011^33^ Test-retest EGRF (lung) Low | NA Lab developed | FFPE and frozen DNA PCR: PCR-invader method | Nonsmall cell lung cancer BML EGFR mutations at exons 18 to 21 54
Pang, 2011^48^ Validation KRAS (colorectal) High | Qiagen Vendor | FFPE DNA PCR amplification | Stage IV colorectal adenocarcinoma Authors’ lab(s) KRAS mutations at exons 2 and 3 11
Pang, 2011^48^ Validation BRAF (colorectal) High | Qiagen Vendor | FFPE DNA PCR amplification | Stage IV colorectal adenocarcinoma Authors’ lab(s) BRAF mutations at exon 15 11
Poulet, 2012^47^ Test-retest MammaPrint (breast) Unclear | NR NR | Frozen DNA Microarray | ER+, HER2-neg early breast cancer Authors’ lab(s) Cluster analysis 67
Poulet, 2012^47^ Test-retest Oncotype DX (breast) Unclear | NR NR | Frozen RNA RT-PCR of 12-gene Recurrence Score Assay | ER+, HER2-neg early breast cancer Authors’ lab(s) Expression levels 67
Sriram, 2011^33^ Cohort EGFR (lung) Low | NA Lab developed | Frozen DNA ME-PCR; HRM | Nonsmall cell lung cancer NR EGFR mutations(exon 19 deletion and exon 21 L858R) 522 tumor tissue and 64 matched serum samples
Van’t Veer, 2002^49^ Validation MammaPrint (breast) Medium | NA Lab developed | Frozen DNA Microarray | Breast cancer Authors’ lab(s) Cluster analysis 78 in development set, 19 in validation set

Abbreviations: ARMS = Amplification Refractory Mutation System; ARMS/S = Amplification Refractory Mutation System and a Scorpion fluorescent primer/probe system; BML = Bio Medical Laboratories (Tokyo, Japan); BRAF = v-Raf murine sarcoma viral oncogene homolog B1; DNA = deoxyribonucleic acid; EGFR = epidermal growth factor receptor gene; FFPE = formalin-fixed, paraffin-embedded; HRM = high-resolution melting; KRAS = V-Ki-ras2 Kirsten rat sarcoma viral oncogene homolog; ME = mutant enriched; NA = not applicable; NOS = not otherwise specified; NR = not reported; PCR = polymerase chain reaction; PNA = peptide nucleic acid; RH = reverse hybridization.

Of the 11 potentially considered molecular pathology tests of interest, we found published studies rated as low or medium RoB for 6 tests: MammaPrint mRNA expression for breast cancer, EGFR mutations and KRAS mutations for lung cancer, KRAS mutations and BRAF mutations for colorectal cancer (CRC), and Oncotype DX Colon mRNA expression for CRC. The published studies that we identified reporting on ALK cytogenetics for lung cancer, Oncotype DX Breast mRNA expression for breast cancer, and MLH1 promoter methylation for CRC were rated as high or unclear RoB. Results of the included studies are provided in Table 6.

Table 6 Results of included studies reporting on analytic validity, by test and cancer

Author, Year, Design, Test (Primary Site), Risk of Bias | Tissue Sample Requirements, Type of Analyte, Measure Technique | Neoplasms, Lab Reporting Results, Test Measure, Sample Size | Marker Sensitivity | Marker Specificity | Cross-Lab Validity Checked, Degree of Cross-Lab Variation
Abbot Labs, 2011^32^ Validation ALK (lung) Unclear | FFPE DNA Fluorescence in situ | Nonsmall cell lung cancer Abbot Labs Chromosome rearrangements 136 | Vysis LSI 3′-ALK SO: 100% 95% CI, (98.5 to 100.0) Vysis LSI 5′-ALK SGn: 100% 95% CI, (98.5 to 100.0) | Vysis LSI 3′-ALK SO: 100% 95% CI, (97 to 100.0) Vysis LSI 5′-ALK SGn: 100% 95% CI, (97 to 100.0) | Yes Median Kappa score: 0.92 (range: 0.85 to 0.98)
Angulo, 2013^50^ Test-retest EGFR (lung) Low | FFPE DNA PCR followed by therascreen EGFR Mutation Kit; Sanger sequencing | Nonsmall cell lung cancer Histology: Carcinomas NOS (23.5%) Squamous cell carcinomas (10.3%) Adenocarcinomas (64%) Large cell carcinomas (2.2%) Authors’ lab(s) EGFR mutations at exons 19 to 21 136 samples | Exon 19 deletion: 100% Exon 21 L858R: 100% Exon 20 insertion: 67.75% All mutations :94.7% | Exon 19 deletion: 100% Exon 21 L858R: 100% Exon 20 insertion: 100% All mutations : 100% | No NA
Bando, 2010^34^ Validation KRAS (colorectal) Medium | FFPE DNA Direct (Sanger) sequencing; therascreen KRAS Mutation Kit: Allele-specific PCR with Scorpion fluorescent probes (ARMS/S); KRAS Strip-Assay: Reverse hybridization (RH) | CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 100 | RH: 51/74 (69%) ARMS/S: 56/74 (76%) | RH: 25/26 (96%) ARMS/S: 26/26 (100%) | No NA
Beau-Faller, 2011^35^ Validation EGFR (lung) Low | FFPE and frozen DNA Direct or nested Sanger sequencing; each center used its own standard procedure. | Nonsmall cell lung cancer NR EGFR mutations at exons 18 to 21 74 | False positive results, median (range) Exon 19: 0% (0–27%) Exon 21: 17% (0–37%) False positive results, number of centers with false positive rate Exon 19: 0%–9/15 >0%–<10%: 1/15 ≥10%: 5/15 Exon 21: 0%: 7/15 >0–<10%: 0/15 ≥10%–8/15 | False negative results, median (range) Exon 19: 2% (0–9%) Exon 21: 3% (0–6%) False negative results, number of centers with false positive rate Exon 19: 0%: 6/15 >0–<10%: 9/15 ≥10%: 0/15 Exon 21: 0%: 6/15 >0–<10%: 9/15 ≥10%: 0/15 | Yes EGFR Exon 19: Median Kappa score: 0.52 (range: 0.23–0.73) EGFR Exon 21: Median Kappa score: 0.37 (range: 0.20–0.57)
Beau-Faller, 2009^36^ Test-retest KRAS (lung) Low | Frozen DNA PNA-mediated PCR clamping Sanger sequencing | Nonsmall cell lung cancer Authors’ lab(s) KRAS mutations at codons 12 and 13 114 | NR | NR | No NA
Beau-Faller, 2011^35^ Validation KRAS (lung) Low | FFPE and frozen DNA Direct or nested sequencing; each center used their own standard procedure. | Nonsmall cell lung cancer NR KRAS mutations at exon 2 74 | False positive results, median (range) 8% (0–25%) False positive results, number of centers with false positive rate 0%–5/15 >0%–<10%: 4/15 ≥10%: 6/15 | False negative results, median (range) 9% (2–17%) False negative results, number of centers with false positive rate 0%: 0/15 >0%–<10%: 8/15 ≥10%: 7/15 | Yes Median Kappa score: 0.39 (range: 0.15–0.66)
Clark-Langone, 2010^37^ Test-retest Oncotype DX (colorectal) Medium | FFPE RNA RT-PCR of 12-gene Recurrence Score Assay | Stage II adenocarcinoma and mucinous carcinoma Authors’ lab(s) Expression levels NR | NR | NR | No NA
Cronin, 2007^38^ Test-retest Oncotype Dx (breast) Unclear | FFPE RNA RT-PCR of 21-gene Recurrence Score Assay | Node-negative, estrogen receptor–positive breast cancer Vendor’s lab Expression levels NR | NR | NR
Delahaye, 2013^39^ Test-retest MammaPrint (breast) Medium | Fresh tissue RNA Microarray | Early-stage, invasive breast cancer Vendor’s labs Expression levels N = 100 (cross-lab validation) N = 302 (PPV and NPV) | DMFS PPV (95% CI) (5 years): 0.22 (0.16 to 10.28) Overall survival PPV (95% CI) (10 years): 0.29 (0.22 to 20.35) | DMFS NPV (95% CI) (5 years): 0.95 (0.91 to 90.99) [see comment bubble] Overall survival NPV (95% CI) (10 years): 0.90 (0.85 to 80.96) | Yes 99%
Feigelson, 2012^40^ KRAS (colorectal) Low | FFPE DNA PCR amplification followed by Direct Sanger sequencing, PCR amplification followed by standard bidirectional sequencing, PCR amplification followed by sequencing, Single nucleotide primer extension with fragment analysis by capillary electrophoresis using a modified SNaPshot assay, or Qualitative real time PCR. | CRC (18 adenocarcinoma, 2 carcinoma) Genzyme, Clarient, Quest Diagnostics, Henry Ford Health System & Molecular and Medical Genetics-Oregon Health and Science University KRAS mutations at codons 12 and 13 20 | False positive results, number of centers with false positive rate 0%: 3/5 5%: 2/5 | False negative results, number of centers with false positive rate 0%: 4/5 5%: 1/5 | Yes 90% were concordant across all five laboratories
Gao, 2010^41^ Validation KRAS (colorectal) Unclear | FFPE DNA Dideoxy sequencing, KRAS StripAssay and pyrosequencing | CRC Authors’ lab(s) KRAS mutation—exon 2 100 | Pyrosequencing=5% KRAS strip assay=1% dideoxy=15% | NR | No NA
Gonzalez de Castro, 2012^42^ Test-retest KRAS (colorectal) Low | FFPE DNA Cobas EGFR Mutation Test (AS-PCR) therascreen EGFR29 Mutation Kit (ARMS); 2× bidirectional; Sanger sequencing | CRC 2 clinical site labs KRAS mutations at codons 12 and 13 115 | Cobas KRAS and Sanger Sequencing (N=113): PPA=98.2% | Cobas KRAS and Sanger Sequencing (N=113): NPA=89.7% | Yes Cobas KRAS test reproducibility between the two sites:110/112 (98.2%) produced concordant results
Hancer, 2011^43^ Cohort KRAS (colorectal) Unclear | FFPE DNA therascreen KRAS kit Entrogen KRAS mutation analysis kit Dideoxy sequencing, | Adenocarcinomas of the colon and the rectum Authors’ lab(s) KRAS mutation—exon 2 64 | NR | NR | No NA
Jancik, 2012^44^ Test-retest KRAS (lung) High | Frozen DNA Direct sequencing, Pyrosequencing, and the therascreen DxS and KRAS StripAssay kits All of the above as well as high-resolution melting analysis (HRM) | Nonsmall cell lung cancer Authors’ lab(s) KRAS mutations at codons 12 and 13 131 | therascreen DxS kit: 95% KRAS StripAssay: 90% HRM: 70% Pyrosequencing: 48% Sequencing: 29%. | therascreen DxS kit, sequencing, and pyrosequencing: 100% HRM: 98% KRAS StripAssay: 95% | No NA
Kobunai, 2010^45^ Test-retest KRAS (colorectal) Low | Frozen DNA Peptide nucleic acid (PNA)-clamp real-time PCR Sanger sequencing | CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 224 | NR | NR | No NA
Lopez-Rios, 2013^46^ Test-retest EGFR (lung) Low | FFPE DNA Cobas EGFR Mutation Test (AS-PCR); therascreen EGFR29 Mutation Kit (ARMS); 2× bidirectional; Sanger sequencing | Nonsmall cell lung cancer 2 clinical site labs EGFR mutations at exons 18 to 21 124 | AS-PCR test and Sanger: (N=113): PPA of 98.8% | AS-PCR test and Sanger: (N=113): NPA of 79.3% | Yes AS-PCR test reproducibility between the two sites: 122/123 (99.2%) produced concordant results
Mancini, 2010^47^ Test-retest BRAF (colorectal) Medium | Frozen DNA PCR: Cold PCR—sensitivity then evaluated by HRM analysis and Sanger sequencing | Sporadic CRC Authors’ lab(s) BRAF mutations at exon 15 117 | NR | NR | No NA
Mancini, 2010^47^ Test-retest KRAS (colorectal) Medium | Frozen DNA PCR: Cold PCR—sensitivity then evaluated by HRM analysis and sequencing | Sporadic CRC Authors’ lab(s) KRAS mutations at codons 12 and 13 117 | NR | NR | No NA
Naoki, 2011^51^ Test-retest EGRF (lung) Low | FFPE and frozen DNA PCR: PCR-invader method; Sanger sequencing | Nonsmall cell lung cancer BML EGFR mutations at exons 18 to 21 54 | 94.44% (derived from study) | 79.17% (derived from study) | No NA
Pang, 2011^48^ Validation KRAS (colorectal) High | FFPE DNA KRAS PCR | Stage IV colorectal adenocarcinoma Authors’ lab(s) KRAS mutation—exons 2 and 3 11 | NR | NR | No NA
Pang, 2011^48^ Validation BRAF (colorectal) High | FFPE DNA BRAF PCR | Stage IV colorectal adenocarcinoma Authors’ lab(s) BRAF mutation—exon 15 11 | NR | NR | No NA
Poulet, 2012^52^ Test-retest MammaPrint (breast) Unclear | Frozen DNA Microarray | ER+, HER2− early breast cancer Authors’ lab(s) Cluster analysis 67 | NR | NR | No NA
Poulet, 2012^52^ Test-retest Oncotype DX (breast) Unclear | Frozen RNA RT-PCR of 12-gene Recurrence Score Assay | ER+, HER2− early breast cancer Authors’ lab(s) Expression levels 67 | NR | NR | No NA
Sriram, 2011^53^ Cohort EGFR (lung) Low | Frozen DNA ME-PCR; HRM Sanger sequencing | Nonsmall cell lung cancer NR EGFR mutations (exon 19 deletion and exon 21 L858R) 522 tumor tissue and 64 matched serum samples | ME-PCR:100% HRM: 100% | ME-PCR: 99% HRM: 100% | No NA
Van’t Veer, 2002^49^ Validation MammaPrint (breast) Medium | Frozen DNA Microarray | Breast cancer Authors’ lab(s) Cluster analysis 78 in development set, 19 in validation set | NR | NR | No NA

Abbreviations: ARMS = Amplification Refractory Mutation System; AS = Allele-Specific; BML = Bio Medical Laboratories (Tokyo, Japan); BRAF = gene name; DNA = deoxyribonucleic acid; EGFR = gene name; ER = estrogen receptor; FFPE = formalin-fixed, paraffin-embedded; HER2 = Human Epidermal Growth Factor Receptor 2, also known as (Neu); HRM=high-resolution melting; KRAS = gene name; ME = mutant enriched; N = number of samples; NA = not applicable; NOS = not otherwise specified; NPA = negative percent agreement; NR = not reported; PCR = polymerase chain reaction; PNA= peptide nucleic acid; PPA = positive percent agreement; RH = reverse hybridization; SGn = SpectrumGreen; SO = SpectrumOrange.

Data from the College of American Pathologists’ for EGFR mutations, KRAS mutations, BRAF mutations, microsatellite instability for colorectal cancer, and UroVysion cytogenetics for urinary bladder cancer support the analytic validity of these tests (see data in relevant sections below).

#### Breast Cancer: MammaPrint

##### Characteristics of Included Studies Assessing Analytic Validity of MammaPrint

MammaPrint uses a 70-gene signature to classify breast carcinoma patients into those with a good or poor prognosis, based on risk of distant metastasis.

One study by Poulet52 was rated unclear in terms of RoB and is excluded from the description of results below.

Two MammaPrint studies were rated as low or medium RoB (Table 5).39,49 van’t Veer49 developed the 70-gene signature prognostic assay (now known as MammaPrint) for risk of recurrence in early-stage breast cancer, and tested prediction to metastases in 97 patients. Delahaye,39 affiliated with Agendia NV, studied the analytical performance of MammaPrint, including reproducibility, precision, repeatability, tumor heterogeneity, and inter-lab reproducibility.

##### MammaPrint: Analytic Validity

Both MammaPrint studies indicated that the MammaPrint test is precise, repeatable (98.5 to 99 percent), and reproducible for prediction of metastasis in breast cancer (Table 6). The largest contributor to assay variation was intratumor heterogeneity, which is significantly greater than the technical variation in the MammaPrint test.

#### Nonsmall Cell Lung Carcinoma: EGFR and KRAS Mutations

##### Characteristics of Included Studies Assessing Analytic Validity of EGFR Mutation

We reviewed the analytic validity of tests that detected mutations in the EGFR gene. All studies looked at mutations in the gene within exons 18, 19, and/or 21.

We rated 5 studies reporting analytic validity of EGFR testing for lung cancer as having low RoB (Table 5). Angulo50 compared therascreen EGFR mutation screening to direct sequencing of EGFR in FFPE lung tumor tissue. Lopez-Rios46 compared the Cobas EGFR Mutation Test and therascreen EGFR Mutation Test with direct sequencing of EGFR in FFPE lung carcinoma tissue. Sriram53 compared mutant-enriched-PCR and high-resolution melting methods in frozen lung tissue, a subset (97 of 522 samples) of which were previously DNA sequenced in the EGFR gene. Naoki51 compared the PCR-invader method with direct DNA sequencing in FFPE lung tissue and pleural and pericardial effusions. Beau-Faller35 compared several PCR-based methods to direct DNA sequencing of EGFR in FFPE lung tissue across 15 centers.

Also, we received results of proficiency testing from The College of American Pathologists (CAP) to address intralab reproducibility of EGFR mutation testing.

##### EGFR Mutation: Analytic Validity

In general, all five EGFR testing studies for lung cancer compared various PCR-based methods against one another or against DNA sequencing in FFPE tissue (Table 6). All of these studies found that, compared with DNA sequencing, PCR-based methods of screening for EGFR mutations had a lower limit of detection and thus were more sensitive in samples with <20% carcinoma. However, because PCR-based methods are based on known mutations found between exons 18 and 21 of the EGFR gene, DNA sequencing is a better method for identifying novel mutations and mutations elsewhere in the gene.

The CAP sends proficiency test EGFR unknowns to CLIA-approved US clinical laboratories or International clinical laboratories for assessing nationwide interlab reproducibility. The three most recent surveys54 found accuracy rates of 93 percent (122/131; EGFR-B, 2012), 96 percent (157/164; EGFR-A, 2013), and 96 percent (195/204; EGFR-B, 2013), for an average diagnostic accuracy of 94 percent (474/499).

##### Characteristics of Included Studies Assessing Analytic Validity of KRAS Mutation in Nonsmall Cell Lung Carcinoma

We reviewed the analytic value of tests that detected mutations in the KRAS gene. The studies looked at mutations at codons 12 and 13 or on exon 2 in the KRAS gene but not at codon 61.

One study by Jancik44 was rated as having a high RoB and is excluded from the description of results below.

We rated two KRAS mutant lung cancer studies as having low RoB (Table 5). Beau-Faller (2009)36 compared peptide-nucleic-acid-mediated PCR clamping to direct DNA sequencing in frozen lung tissue. Beau-Faller (2011)35 compared several PCR-based methods to direct DNA sequencing of KRAS in FFPE lung tissue across 15 centers.

Also, we received results of proficiency testing from CAP to address intralab reproducibility of KRAS mutation testing.

##### KRAS Mutation for Lung Cancer: Analytic Validity

Both of the KRAS mutant lung cancer studies (Table 6) found that, compared with DNA sequencing, PCR-based methods of screening for KRAS mutations had a lower limit of detection, and thus were more sensitive when the samples contained <20% carcinoma.

CAP sends proficiency test KRAS unknowns to CLIA-approved US clinical laboratories or International clinical laboratories for assessing nationwide interlab reproducibility. The three most recent surveys55 found accuracy rates of 98 percent (194/197; KRAS-B, 2012), 98 percent (206/209; KRAS-A, 2013), and 98 percent (211/215; KRAS-B, 2013), for an average diagnostic accuracy of 98 percent (611/621).

##### Characteristics of Included Studies Assessing Analytic Validity of ALK Translocation

There were no published studies that provided any information about the analytic validity of the ALK Translocation test. Abbot Labs, 2011^32^ has information provided with their Vysis ALK Break Apart FISH Probe Kit literature on specific performance characteristics, including analytical sensitivity and specificity, tissue reproducibility, and external reproducibility (Tables 5 and 6). This work was rated unclear in terms of RoB and is excluded from the description of results.

#### Colorectal Carcinoma

##### Characteristics of Included Studies Assessing Analytic Validity of BRAF Mutation

The BRAF mutation tests being examined in this report screen for the V600E mutation in the BRAF gene.

One study by Pang (2011)48 was rated as having a high RoB and is excluded from the description of results below.

A single BRAF CRC study had a rating of medium RoB (Table 5). Mancini47 compared a novel lower denaturation temperature PCR (COLD-PCR) with the more traditional high-resolution melting (HRM) PCR method in screening for BRAF c.1799 T>A (p.V600E) mutation.

Also, we received results of proficiency testing from CAP to address intralab reproducibility of BRAF mutation testing.

##### BRAF Mutation: Analytic Validity

Mancini47 found that COLD-PCR was more sensitive than HRM-PCR for detecting the BRAF mutation (Table 6).

The College of American Pathologists sends proficiency test BRAF unknowns to CLIA-approved U.S. clinical laboratories or International clinical laboratories, an excellent mechanism for assessing inter-lab reproducibility. The three most recent surveys56 found accuracy rates of 100% (140/140; BRAF-B, 2012), 98% (192/195; BRAF-A, 2013), and 98% (196/200; BRAF-B, 2013), for an average diagnostic accuracy of 99% (528/535).

##### Characteristics of Included Studies Assessing Analytic Validity of KRAS Mutation in Colorectal Carcinoma

The genetic test for KRAS mutations described here checks for mutations in codons 12 and 13 in the KRAS gene but not in codon 61.

One study by Pang48 was rated as having a high RoB, and two studies—Gao41 and Hancer43—were rated as having unclear RoB and are excluded from the description below.

We rated five KRAS mutant CRC studies as having low to medium RoB (Table 5). Mancini47 compared COLD-PCR with the HRM PCR method in screening for KRAS mutations in frozen colorectal tissue. Kobunai45 compared peptide nucleic acid-clamp PCR with direct sequencing in frozen colorectal tissue. Gonzalez de Castro42 compared the cobas KRAS Mutation Test and the Qiagen therascreen KRAS Kit methods to direct KRAS sequencing in FFPE colorectal tissue. Bando34 compared the KRAS StripAssay and therascreen KRAS Mutation kit with direct KRAS sequencing. Feigelson40 compared five different KRAS mutation testing regimens for comparability and consistency across five laboratories.

Also, we received results of proficiency testing from CAP to address intralab reproducibility of KRAS mutation testing.

##### KRAS Mutation for Colorectal Carcinoma: Analytic Validity

All of these studies found that, compared with DNA sequencing, PCR-based methods of screening for KRAS mutations had a lower limit of detection, and thus were more sensitive in samples with <20% carcinoma (Table 6).

CAP sends proficiency test KRAS unknowns to CLIA-approved US clinical laboratories or International clinical laboratories for assessing nationwide interlab reproducibility. The three most recent surveys55 found accuracy rates of 98 percent (194/197; KRAS-B, 2012), 98 percent (206/209; KRAS-A, 2013), and 98 percent (211/215; KRAS-B, 2013), for an average diagnostic accuracy of 98 percent (611/621).

##### Characteristics of Included Studies Assessing Analytic Validity of MSI

We found no individual published studies meeting our inclusion criteria that reported eligible information on analytic validity of the microsatellite instability (MSI) test for CRC.

We received results of proficiency testing from CAP to address intralab reproducibility of MSI testing.

##### MSI for Colorectal Carcinoma: Analytic Validity

CAP sends proficiency test MSI unknowns to CLIA-approved US clinical laboratories or International clinical laboratories for assessing nationwide interlab reproducibility. The three most recent surveys57 found accuracy rates of 100 percent (89/89; MSI-B, 2012), 99 percent (96/97; MSI-A, 2013), and 98 percent (103/105; MSI-B, 2013), for an average diagnostic accuracy of 99 percent (288/291).

##### Characteristics of Included Studies Assessing Analytic Validity of Oncotype DX (for Breast and Colon)

Oncotype DX Breast and Oncotype DX Colon are mRNA abundance assays performed on formalin-fixed paraffin-embedded tissue. They are not intended to act as surrogate tests for identifying underlying gene mutations. Selected mRNA abundance differences have been correlated with known clinical outcomes and are now used to predict risk of recurrence and to guide adjuvant therapy use in new patients who have undergone resection of their primary carcinomas for cure. Oncotype DX Breast uses a 21-gene mRNA expression signature and assigns a recurrence risk score (RS) ranging from 0 to 100 for each patient. Oncotype DX Colon uses a 12-gene mRNA expression signature and assigns an RS ranging from 0 to 100 for each patient.

The Cronin lab at Genomic Health measured intralaboratory detectability, dynamic range, and reproducibility for assays on this set of 21 mRNAs for Oncotype DX Breast.38 This study was rated as having unclear RoB (Table 5). Published data on Oncotype DX Colon by Clark-Langone,37 affiliated with the Cronin lab and referencing the above paper, provided similar analytical validity data for the 12-gene Oncotype DX Colon assay.

##### Oncotype DX: Analytic Validity

The data from Cronin’s group at Genomic Health38 found high intralab reproducibility for Oncotype quantitative RT-PCR mRNA abundance measurements relevant to the Oncotype DX tests for breast and colon carcinoma. Clark-Langone37 reported high analytic validity and precision for the Oncotype DX Colon assay (Table 6). No references were found to estimate interlaboratory reproducibility, because this assay is not performed outside of Genomic Health.

#### Bladder Cancer: UroVysion

##### Characteristics of Included Studies Assessing UroVysion

UroVysion is a fluorescence in situ hybridization (FISH) test of exfoliated urothelial cells that has been shown to be sensitive in terms of diagnosing urothelial cancer.

We found no individual published studies meeting our inclusion criteria that reported eligible information on analytic validity of the UroVysion test for bladder cancer.

We received results of proficiency testing from CAP to address intralab reproducibility of UroVysion testing.

##### UroVysion: Analytic Validity

CAP sends proficiency test UroVysion unknowns to CLIA-approved US clinical laboratories or International clinical laboratories for assessing nationwide interlab reproducibility. The four most recent surveys58 found accuracy rates of 99 percent (168/170; UroVysion-A, 2013), 99 percent (168/170; UroVysion-B, 2013), 99 percent (191/192; UroVysion-C, 2013), and 100 percent (193/193; UroVysion-D, 2013), for an average diagnostic accuracy of 100 percent (552/555).

#### Clinical Validity: Breast Cancer: MammaPrint and Oncotype DX

##### Characteristics of Included Studies Assessing Clinical Validity of MammaPrint

We found 11 studies49,59–68 that reported on the prognostic value of the RS from MammaPrint for RR, CSS, or OS in patients with breast cancer (Table 7). All were cohort studies. Sample sizes ranged from 89 to 964. Median followup was 3 to 10 years. Eight out of 10 studies were conducted in the Netherlands either exclusively by the group that developed the signature or in collaboration with other European countries. One study was conducted in the United States,61 and one was conducted in France, Sweden, and the United Kingdom.60

All studies compared outcomes of patients who had a good prognosis signature with those who had a poor prognosis signature. Age of the women in the studies for which age is reported was approximately 50 years, although a couple of studies included women who were in their twenties. Race or ethnicity was not reported in any of the studies.

There were some differences in the populations enrolled in the included studies. Differences were in stage and ER, node positivity, and age. Three studies restricted the sample to node-negative cancers,59,60,65 a couple included cases with one to three positive nodes,63,67 one looked at patients with four to nine positive nodes68and two included stages I through III,62,63 whereas the others restricted the study to stage I or II.

Table 7 Characteristics of included studies: MammaPrint for breast cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Bueno-de-Mesquita 2009^59^ Cohort Low | 151 Median 10.2 years (0.7–21.3) | The Netherlands | Early stage Node-negative breast cancer, tumor diameter pT1–2. | Good prognosis signature Poor prognosis signature | NR NR | Mean (range): 47 (27–55)
Buyse, 2007^60^ Cohort Unclear | 307 Median: 13.6 years | France, Sweden, and United Kingdom | I–II Node negative | Good prognosis Poor prognosis | NR NR | Median: 58 100%
Iwamoto, 2011^61^ Cohort Unclear | 228 Median 56.4 (5.9 to 60) months | United States | I–III ER-positive and -negative cancers as well as low and high histologic grade tumors | Good prognosis Poor prognosis | NR NR | 51.9 (26–79) NR
Knauer, 2010^62^ Cohort Low | 89 | The Netherlands, Austria, and Belgium | I–III Unilateral HER2 positive invasive breast carcinoma, no chemotherapy, no trastuzumab | Good prognosis Poor prognosis | NR NR | Median (range): 50 (28–79) 100%
Mook, 2009^63^ Cohort Low | 241 | The Netherlands, Italy | II–III (T stage 1–3 with 1–3 positive lymph nodes) | Good prognosis Poor prognosis | NR NR | NR NR
Mook, 2010^64^ Pooled analysis of multiple cohorts Low | 964 Median (range): 7.1 (0.2–25.2) years | The Netherlands | pT1 including 1a, 1b, and 1c tumors | Good prognosis Poor prognosis | NR NR | NR NR
Mook, 2010^65^ Cohort Medium | 148 Median (range): 375.1 (41.7 to 922.2) weeks | The Netherlands | I–II Node negative | Good prognosis Poor prognosis | NR NR | Range 55–70 100%
Nuyten, 2008^66^ Cohort Medium | 144 Median (range): 10.2 (0.05 to 21.7) years | The Netherlands | II Node positive | Good prognosis Poor prognosis | NR NR | NR NR
Saghatchian, in press68 Cohort Medium | 173 Median, 7.9 years | The Netherlands, Italy | Primary invasive breast cancer with 4 – 9 positive nodes, T1-3, estrogen receptor +/−, progesterone receptor +/−, HER2 +/− | Genomic high risk Genomic low risk | | Age for each group, mean (SD): GHR = 49.1 (9.7); GLR = 51.4 (9.5 100%
Van’t Veer, 2002^49^ Cohort Medium | 98 | The Netherlands | Sporadic breast cancer 55 years or younger, 18 cases of BRCA1 and 2 BRCA2 | Good prognosis Poor prognosis | NR NR | All patients were younger than 55 years at diagnosis 100%
Van de Vijver, 2002^67^ Cohort Low | 295 Median (range): 7.8 years (0.05 to 18.3) years (207 patients without metastasis as the first event) Median (range): 2.7 (0.3 to 14.0) years (88 patients with metastasis as the first event). Median (range): 6.7 (0.05 to 18.3) years (all 295 patients) | The Netherlands | I–II | Good prognosis Poor prognosis | NR NR | All patients were younger than 53 years 100%

Abbreviations: HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu; MUT = mutation; N = number; NR = not reported; SD = standard deviation.

#### MammaPrint: Risk of Recurrence

Six cohort studies rated as low or medium RoB reported RR (total N=1,913).59,62–64,67,68 All studies used distant metastasis-free survival (DMFS) instead of recurrence-free survival (local and distant recurrence) as their outcome. All six reported on the prognostic value of MammaPrint after controlling for traditional prognostic factors such as stage, size, and differentiation, for example. One study used the composite score from Adjuvant! Online—an online program that combines traditional prognostic factors to calculate an RS.69 All studies concluded that patients with a poor prognosis signature had a higher risk of distant metastasis compared with patients with a good prognosis signature. The hazard ratios (HRs) in these studies ranged from 2.43 to 5.8, and all the studies had overlapping 95% confidence intervals (Table 8).

Table 8 Breast Cancer: MammaPrint risk of distant metastasis-free survival

Author, Year, Design, N, Risk of Bias | Adjusted HR (95% CI), p-value | Variables Used in Multivariate Model
Knauer, 2010^62^ Cohort 89 Low | DMFS HR: 5.8 (1.25 to 26.66) p=0.025 | Age at diagnosis, tumor size, number of positive lymph nodes, histological grade (1/2 vs. 3), ER status, progesterone receptor (PR) status, adjuvant hormonal therapy
Bueno-de-Mesquita 2009^59^ Cohort 151 Low | DMFS RS in NKI-RdGG series HR: 4.8 (1.3 to 17) RS in updated validation series HR: 5.3 (95% CI: 2.4 to 12) | Performance of 70-gene prognosis signature vs. performance of predictor with results for 4 different models; results from Adjuvant! Online
Mook, 2009^63^ Cohort 241 Low | DMFS HR: 3.0 (1.0 to 9.0) p=0.05 | Age (years); number of positive nodes: 2 vs. 1 and 3 vs. 1; tumor size (20 mm vs. ≤20 mm); histological grade: moderate vs. good, poor vs. good; ER status; HER2 receptor status; surgery (mastectomy vs. breast conservation therapy [BCT]) chemotherapy; endocrine therapy; prognosis signature (poor vs. good signature)
Mook, 2010^64^ Pooled analysis of several cohorts 964 Medium | DMFS HR: 2.43 (1.56 to 3.77) p<0.001 | Age, histology, tumor size, nodal status, grade, ER status, HER2 status, type of surgery, hormonal therapy (yes/no), chemotherapy (yes/no), 70-gene signature
Saghatchian, in press68 Cohort 173 Medium | DMFS MammaPrint, low risk vs. high risk, main analysis HR: 1.888 (0.953 to 3.739) p=0.068 DMFS MammaPrint, low risk vs. high risk, subgroup analysis (N=129 women with 4 to 9 positive nodes) 2.698 (1.267 to 5.748) p=0.010 | Main analysis: Age, invasive ductal carcinoma, number of positive nodes, grade, ER status, PR status, and HER2 status Subgroup analysis: Age, invasive ductal carcinoma, number of positive nodes, grade
Van de Vijver, 2002^67^ Cohort 295 Low | DMFS HR: 4.6 (2.3 to 9.2) p<0.001 | Age, lymph node status, diameter of tumor, tumor grade, vascular invasion, estrogen receptor status, mastectomy, chemotherapy, hormonal treatment

Abbreviations: BCT = breast conservation therapy; CI = confidence interval; ER =estrogen receptor; HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu; HR = hazard ratio; mm = millimeter; N = number; N+ = number positive; NKI-RdGG = the name of a clinical trial; p = probability; PR = progesterone receptor; RS = risk score.

Using a fixed effects model, our meta-analysis found a greater risk of recurrence for the poor prognosis group than for the good prognosis group (HR, 2.84; 95% CI, 2.11 to 3.82; Figure 4).

Figure 4 Prognostic value of MammaPrint for risk of recurrence, meta-analysis of adjusted hazard ratios

Figure 4 is titled "Prognostic Value of MammaPrint for Risk of Recurrence, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 6 studies reporting the adjusted hazard ratios for the risk of breast cancer recurrence for patients in the poor prognosis group versus the good prognosis group as determined by MammaPrint. The figure is further described in the "MammaPrint: Risk of Recurrence" section of the report as follows: "Using a fixed effects model, our meta-analysis found a greater risk of recurrence for the poor prognosis group than for the good prognosis group (HR, 2.84; 95% CI, 2.11 to 3.82)."

#### MammaPrint: Cancer-Specific Mortality

Five studies (N=1,615) rated as medium RoB reported on CSS for MammaPrint.62–65,68

The reported HRs are from models that controlled for traditional prognostic factors such as histology, size, and nodal status. Mook (2010)65 used Adjuvant! Online that combines various clinic pathological factors to create an RS; the remaining studies included the clinic pathological factors in the model. All studies reported that patients with a poor prognosis signature had a higher cancer-specific mortality rate than those with a good prognosis signature (Table 9).

Table 9 Breast cancer: MammaPrint cancer-specific survival

Author, Year, Design, Number of Patients, Risk of Bias | HR (95% CI), | p-value | Variables Used in the Multivariate Model
Knauer, 2010^62^ Cohort 89 Medium | 4.7 (1.01 to 21.75) | p=0.048 | Age at diagnosis, tumor size, number of positive lymph nodes, histological grade (1/2 vs. 3), ER status, PR status, adjuvant hormonal therapy
Mook, 2010^65^ Cohort 148 Moderate | 14.4 (1.7 to 122) at 5 years | p=0.01 | Adjuvant! Online score, which incorporates age, tumor size and grade, lymph node status, health status, hormone receptors
Mook, 2010^64^ Pooled analysis of several cohorts 964 Moderate | 3.25 (1.92 to 5.51) | p<0.001 | Age, histology, tumor size, nodal status, grade, ER status, HER2 status, type of surgery, hormonal therapy (yes/no), chemotherapy (yes/no), 70-gene signature
Mook, 2009^63^ Cohort 241 Low | 7.2 (1.8 to 28.4) | p=0.005 | Age (years), number of positive nodes: 2 vs. 1 and 3 vs. 1, tumor size (20 mm vs. ≤20 mm) Histological grade: moderate vs. good, poor vs. good, ER status, HER2 receptor status, surgery (mastectomy vs. BCT) chemotherapy, endocrine therapy, prognosis signature (poor vs. good signature)
Saghatchian, in press68 Cohort 173 Medium | MammaPrint, low risk vs. high risk, main analysis 1.971 (0.897 to 4.330) MammaPrint, low risk vs. high risk, subgroup analysis (N = 129 women with 4 to 9 positive nodes 2.674 (1.069 to 6.685) | p=0.091 p=0.035 | Main analysis: Age, invasive ductal carcinoma, number of positive nodes, grade, ER status, PR status, and HER2 status Subgroup analysis: Age, invasive ductal carcinoma, number of positive nodes, grade

a calculated from years by abstractor

Abbreviations: BCT = breast conservation therapy; CI = confidence interval; ER = estrogen receptor; HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu; HR = hazard ratio; p = probability; PR = progesterone receptor.

Using a fixed effects model, our meta-analysis found a greater RR for the poor prognosis group than for the good prognosis group (HR, 3.3; 95% CI, 2.22 to 4.9) (Figure 5).

Figure 5 Prognostic value of MammaPrint for cancer-specific survival, meta-analysis of adjusted hazard ratios

Figure 5 is titled "Prognostic Value of MammaPrint for Cancer Specific Survival, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 5 studies reporting the adjusted hazard ratio for breast cancer patients with a poor prognosis signature compared with those with a good prognosis signature. The figure is described further in the "MammaPrint: Cancer-specific mortality" section of the report as follows, "Using a fixed effects model, our meta-analysis found a greater RR for the poor prognosis group than for the good prognosis group (HR, 3.3; 95% CI, 2.22 to 4.90)."

#### MammaPrint: Overall Survival

Only one study66 with a moderate RoB rating was available to assess the prognostic value of MammaPrint for overall survival (Table 10). The study included 144 patients and did not find a statistically significant association between test result and survival.

Table 10 Breast cancer: MammaPrint overall survival

Author, Year, Design, N, Risk of Bias | Adjusted Ratios (95% CI), p-value | Variables Used in Multivariate Model
Nuyten, 2008^66^ Cohort N=144 Moderate | Death: HR:1.67 (0.73 to 3.82) p=0.23 | Diameter, grade age; ER status; angio invasion; chemotherapy; hormonal therapy hypoxia-wound signature combination

Abbreviations: CI = confidence interval; ER = estrogen receptor; HR = hazard ratio; p = probability; N = number.

##### Characteristics of Included Studies Assessing the Clinical Validity of Oncotype DX

We included eight studies70–77 that reported on the prognostic value of Oncotype DX Breast for RR, CSS, and OS in patients with breast cancer. Six were cohort studies with sample sizes that ranged from 338 to 1,231. Median followup was between 8 and 10 years. Two studies were case-control studies. Five studies were conducted in the United States, one in Japan, and one in the United Kingdom. Race and ethnicity were not reported for most studies; one study reported enrolling 80 percent non-Hispanic White subjects,71,72 and one reported enrolling 92 percent White subjects.76

All of the cohort studies used tissue collected during large randomized clinical trials. Dowsett70 used tissue from the ATAC trial; Habel sampled cases and controls from the Kaiser Permanente Tumor registry. Paik (2004)74 and Tang76 report on the same 668 patients from the NSABP-14 trial. Mamounas72 includes the 668 patients used in Paik (2004)74 and Tang76 in the 895 patients they report on in their paper. Solin75 used tissue from the E2197 trial. One of the case-control studies identified 165 cases as those who died from breast cancer, and 401 controls matched by age, race, and calendar year71; the other case-control study used 10 cases who had distant metastases and age-matched controls who did not have metastases during the observation period.

Most of the studies included only ER+ patients.72–74,77 Half of the included studies also restricted enrollment to node-negative subjects72–74,76 (Table 11).

Table 11 Characteristics of included studies: Oncotype DX for breast cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Dowsett, 2010^70^ Cohort Medium | 1,231 Median 8.5 years | United Kingdom | Stage NR ER+ breast cancer | RS was a continuous var^a^ | NR NR | Mean 64.1 100%
Habel, 2006^71^ Case-control Low | 566 NR | United States | Stage NR Invasive breast cancer | Low (RS<18) Intermediate (RS 18–30) High (RS>31) | 80% non-Hispanic White | NR 100%
Mamounas, 2010^72^ Cohort Moderate | 895 Median: 12.5 years | United States | Stage NR Node negative, ER+ breast cancer | Low (RS<18) Intermediate (RS 18–30) High (RS>31) | NR NR | NR NR
Mamounas, 2012^73^ Cohort Unclear | 1,065 Median 11.2 years | NR | Stage NR Node positive, ER+ breast cancer | Low (RS<18) Intermediate (RS 18–30) High (RS>31) | NR NR | NR NR
Paik 2004^74^ Cohort Medium | 668 NR | United States | Stage NR Node negative, ER+ breast cancer | Low (RS<18) Intermediate (RS 18–30) High (RS>31) | NR NR | NR NR
Solin 2012^75^ Cohort Medium | 388 Median (range): 9.7 (3.7 to 11.6) years | United States | Stage NR 1–3 positive lymph nodes or negative lymph nodes with tumor size >1.0 cm | Local recurrence Local-regional recurrence | NR NR | NR 100%
Tang, 2011^76^ Cohort Low | 668 Median 14.3 years | United States | NR Node negative, ER+ breast cancer, tamoxifen treated | RS percentile^b^ | White: 615 (92%) Black: 31 (5%) Others: 22 (3%) NR | NR 100%
Yorozuya, 2010^77^ Case-control Medium | 40 (10 cases), 30 controls Median: 232.3 weeks (cases) | Japan | Stage I or Iia, ER+ primary breast cancer | Low (RS<18) Intermediate (RS 18–30) High (RS≥31) (within 2 years) | NR NR | Cases mean (range): 49.1 (37 to 76) Controls mean (range): 50.9 (37 to 78) 100%

a Risk score was a continuous variable, with the HR for distant recurrence calculated relative to an increment of 50 units (e.g., the HR for Risk Score=55 vs. Risk Score=5), chosen to be consistent with prior clinical validation studies.

b RI-PCT had a range from 0 to 100; it was by 50 and rescaled to a range from 0 to 2 in regression analyses so that the associated HRs were comparable to those HRs associated with clinicopathologic factors.

Abbreviations: cm = centimeter; ER = estrogen receptor; MUT = mutation; N = number; NR = not reported; RS = risk score.

#### Oncotype DX: Risk of Recurrence

Six cohort studies70,72,74–77 with low or medium RoB rating (total N=3,222 patients) and a case-control study with 40 patients (10 cases with recurrence and 30 controls) reported on the prognostic value of Oncotype for RR in breast cancer.

Dowsett,70 Paik (2004),74 Tang,76 and Yorozuya77 all used distant recurrence as the primary endpoint. Solin75 and Mamounas72 used loco or loco-regional recurrence (LRR) as the primary end point. All of the included studies reported on the prognostic value of Oncotype DX after controlling for traditional prognostic factors such as stage, size, and differentiation, for example. The number of variables in the models varied across the studies, and a couple looked at the effect of controlling for several combinations of prognostic factors (Table 12). A high RS was consistently shown to be a predictor of distant recurrence but not for LRR

Table 12 Breast cancer: Oncotype DX risk of cancer recurrence (disease-free survival, recurrence-free survival, distant metastasis-free survival)

Author, Year, Design, Number of Patients, Risk of Bias | Adjusted Ratios(95% CI), p-values | Variables Used in Multivariate Model
Dowsett, 2010^70^ Cohort 1,231 Moderate | Distant recurrence N0 patients: HR: 5.25 (2.84 to 9.73) p<0.001 N+ patients: HR: 3.47 (1.64 to 7.38) p=0.002 | Tumor size (>2 vs. ≤2 cm); central grade (moderate vs. well, and poor vs. well); age (<65 vs. ≥65); positive nodes (≥4 vs. 1–3 nodes); positive nodes variable only included in analyses for N+ patients
Mamounas, 2010^72^ Cohort 895 qwModerate | RS as a continuous variable calculated relative to an increment of 50 units: LRR HR: 2.16 (1.26 to 3.68) p=0.005 Intermediate vs. low risk: HR: 2.16 (0.98 to 4.75) p=0.143 High vs. low risk: HR: 1.67 (0.78 to 3.58) p=NR | Age (≥50 vs. <50); mastectomy vs. lumpectomy and radiation therapy; clinical tumor size (>2 vs. ≤2 cm); tumor grade (moderate vs. well); tumor grade (poor vs. well)
Paik 2004^74^ Cohort 668 Medium | RS Distant recurrence HR:3.21 (2.23 to 4.61) p<0.001 | Age, tumor size, RS
Solin 2012^75^ Cohort 388 Medium | NR NS for local or LRR | Chemotherapy arm, patient age, HR status, pathologic axillary lymph node status, histologic grade, pathologic T stage, biologic subtype, and 21-gene RS
Tang, 2011^76^ Cohort 668 Low | Distant recurrence RS-PCT/50 Model 4: HR: 2.83 (95% CI: 1.91 to 4.18) p<0.001 Model 5: HR: 2.37 (95% CI, 1.58 to 3.55) p<0.001 Model 6: HR: 2.34 (95% CI, 1.56 to 3.5) p<0.001 | Model 4: Adjuvant! Online score (RI) as a composite covariate representing common prognostic factors Model 5: included Adjuvant! Online score (RI); also included common prognostic factors as individual covariates including: age (>50 vs. ≤50); tumor size (cm); grade (moderate vs. well); grade (poor vs. well); RI-PCT/50 Model 6: included only individual prognostic factors as covariates including age (>50 vs. ≤50); tumor size (cm); grade (moderate vs. well); grade (poor vs. well); RI-PCT/50
Yorozuya, 2010^77^ Case-control 40 (10 cases), 30 controls) Moderate | OR: 2.85 (95% CI: 0.07 to 115.5) p=0.579 | Age at diagnosis; ER score; PgR score; RS 50 or more vs. RS<50; histological grade lymphatic invasion

a Calculated from years by abstractor

Abbreviations: CI = confidence interval; cm = centimeter; ER = estrogen receptor; HR = hazard ratio; LRR = loco-regional recurrence; N+ = number positive; N0 = node negative; NR = not reported; OR = odds ratio; p = probability; PgR =progesterone receptor; RI = risk index; RI-PCT = risk index percentile; RS = risk score; RS-PCT = risk score percentile; vs. = versus.

Mamounas72 and Solin75 reported that the RS was not a significant predictor of the risk of LRR. Paik and Tang used the same set of patients but fitted different models to assess the prognostic value of the Oncotype DX RS in predicting distant recurrence. Models reported in Paik74 and Tang76 found statistically significant HRs between 2.3 and 3.1. Dowsett70 reported a significant HR for both node-negative (5.25) and node-positive patients (3.47). The case-control study reported that cases having a distant recurrence had a higher RS than age-matched controls with no distant metastasis.

In a fixed effects model, our meta-analysis found an overall HR for RR for the high RS group compared with the intermediate/low RS group of 2.97 (95% CI, 2.19 to 4.0) (Figure 6).

Figure 6 Prognostic value of Oncotype DX Breast for risk of recurrence, meta-analysis of adjusted hazard ratios

Figure 6 is titled "Prognostic Value of Oncotype DX Breast for Risk of Recurrence, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 5 studies reporting the adjusted hazard ratio for risk of breast cancer recurrence for patients with high risk scores compared with those with low risk scores. The figure is described further in the "Oncotype DX: Risk of Recurrence" section of the report as follows: "In a fixed effects model, our meta-analysis found an overall HR for RR for the high risk score group compared with the intermediate/low risk score group of 2.97 (95% CI, 2.19 to 4.0)."

#### Oncotype DX: Cancer-Specific Survival

We found two included studies rated as low RoB that reported on the prognostic value for CSS. One was a cohort study, Tang,76 that included 668 patients, and one was a case-control study, Habel,71 that included 566 patients. Tang76 fit several models to the data and reported HRs ranging from 2 to 2.45, depending on the prognostic variables controlled for. Habel71 reported that both tamoxifen-treated and tamoxifen-untreated breast cancer patients who died had higher RSs than matched patients who survived (Table 13).

Table 13 Breast cancer: Oncotype DX cancer-specific survival

Author, Year, Design, Number of Patients, Risk of Bias | Adjusted Risk (95% CI), p- value | p-value | What Variables Were Used in the Multivariate Model?
Habel, 2006^71^ Case-control 566 Low | RS: Tamoxifen treated RR: 5.3 (1.6 to 17.2) p=0.003 Tamoxifen untreated RR: 2.4 (1.1 to 5.2) p=0.03 | NR | Tumor size continuous (cm); grade (well, moderate, poor); RS (continuous)
Tang, 2011^76^ Cohort 668 Low | RS-PCT/50 Model 4: HR: 2.45 (1.66 to 3.61) p<0.001 Model 5: HR: 2.02 (1.35 to 3.00) p<0001 Model 6: HR: 2.01 (1.35 to 2.98) p<0.001 | NR | Model 4: Adjuvant! Online score (RI) as a composite covariate representing common prognostic factors but did not also include those factors individually Model 5: included Adjuvant! Online score (RI); also included common prognostic factors as individual covariates including age (>50 vs. ≤50); tumor size (cm); grade (moderate vs. well); grade (poor vs. well); RI-PCT/50 Model 6: included only individual prognostic factors as covariates including age (>50 vs. ≤50), tumor size (cm), grade (moderate vs. well), grade (poor vs. well), RI-PCT/50

a calculated from years by abstractor

Abbreviations: cm = centimeter; HR = hazard ratio; p = probability; RI = risk index; RI-PCT = risk index percentile; RR = relative risk; RS = risk score; RS-PCT = risk score percentile.

One cohort study, Tang,76 rated as low RoB, was available. Tang fitted models with different combinations of adjustments for traditional prognostic factors. The HRs were of a similar magnitude in all three models, and the association between high RS and earlier death from all causes was positive and significant (Table 14).

Table 14 Breast cancer: Oncotype DX—overall survival

Author, Year, Design, N, Risk of Bias | Median Length of Followup to Determine Recurrence/Survival | Adjusted Ratio (95% CI), p-values | Variables Used in Multivariate Model
Tang, 2011^76^ Cohort N=688 Low | 14.3 years (range: NR) | RS-PCT/50 Model 4: HR: 1.77 (1.35 to 2.33) p<0.001 Model 5: HR: 1.65 (1.24 to 2.19) p<0.001 Model 6: HR: 1.65 (1.24 to 2.19) p<0.001 | Model 4: Adjuvant! Online score (RI) as a composite covariate representing common prognostic factors but did not also include those factors individually Model 5: included Adjuvant! Online score (RI); also included common prognostic factors as individual covariates including age (>50 vs.≤50), tumor size (cm), grade (moderate vs. well), grade (poor vs. well), RI-PCT/50 Model 6: included only individual prognostic factors as covariates including: age (>50 vs.≤50), tumor size (cm), grade (moderate vs. well), grade (poor vs. well), RI-PCT/50

Abbreviations: CI = confidence interval; HR = hazard ratio; p = probability; NR = not reported; RI = risk index; RI-PCT = risk index percentile; RS = risk score; RS-PCT = risk score percentile.

#### Lung Cancer: EGFR and KRAS Mutations

##### Characteristics of Included Studies Assessing the Clinical Validity of EGFR Mutation Testing

We found 12 studies78–89 that examined the added prognostic value of EGFR mutations in patients with nonsmall cell lung carcinoma (NSCLC). All were cohort studies. Sample sizes ranged from 50 to 524 patients. Median followup was not reported in all studies. Followup varied from 4 to 14 years. Studies were conducted in Japan, South Korea, Taiwan, China, various European countries, and the United States.

All studies primarily compared outcomes of patients with EGFR wild-type to those with EGFR mutations. A few looked at specific mutations such as the exon 19 deletion or the exon 21 L858R. The representation of female patients in the studies ranged from a low of 16 percent to a high of 65 percent. Race or ethnicity was reported only in two studies84,89 conducted in the United States and Canada; Mak84 and Tsao89 had samples with 93 percent and 44 percent white patients, respectively.

Populations represented in the studies varied somewhat. The differences were both in cancer stage and cancer type. Four studies included all four stages,78–80,88 three included stages I to III,82 ,83 ,86 two included only stage I,81,85 and the remaining included stages I and II. Not all studies specify the type of tumors included (Table 15).

Table 15 Characteristics of included studies: EGFR mutation testing for lung cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/Disease Characteristics | Study groups | Race Ethnicity | Overall Age (years) % Female
An, 2012^78^ Cohort Medium | 524 | China | I–IV | | NR NR | Mean (range)=59.3 (23 to 88) 31%
Hiramitsu, 2010^79^ Cohort High | 193 470.4 weeks | Japan | I–IV Primary lung cancer | EGFR-WT EGFR-MUT | NR NR | Mean=63 50.3%
Kim, 2008^80^ Cohort Medium | 71 Mean (SD): 25.3 (11.1) months Range: 2.9 to 47.5 months | Republic of Korea (South Korea) | I–IV | EGFR-WT EGFR-MUT | NR NR | Median (range)=59.6 (38 to 85) 59.2%
Kim,2013^88^ Cohort Medium | 863 23.6 ± 0.7 months | Korea | I–IV | EGFR-MUT | NR | Mean=63 (27 to 87) 40%
Kobayashi, 2008^81^ Cohort Medium | 127 Median (range): 67 (12 to 134) months | Japan | IA Adenocarcinoma of the lung <20 mm diameter | EGFR-WT EGFR-MUT | NR NR | Median (range)=65 (38 to 83) 54.3%
Koh, 2010^82^ Cohort High | 136 Median: 491.3 weeks | Korea | IA–IIB | EGFR-WT EGFR-MUT | NR NR | Median (range)=61 (33 to 80) 26%
Liu, 2010^83^ Cohort Medium | 164 Range: 3.9 to 687 weeks | China (Taiwan) | I–IIIA Adenocarcinoma, squamous cell carcinoma, adenosquamous carcinoma | EGFR-WT EGFR-MUT | NR NR | NR 32.9%
Mak, 2011^84^ Cohort Medium | 123 Median (95% CI): 40.4 (30.5 to 52.6) months | United States | IIB–IIIB | EGFR-WT EGFR-MUT | White:93% Asian: 6% Other: 2% Ethnicity NR | Median (range)=62 (39 to 85) 65%
Matsumoto, 2006^85^ Cohort Medium | 107 Median (range) 63 (4 to 110) months | Japan | I | EGFR-WT EGFR-MUT | NR NR | NR 43%
Rouquette, 2012^86^ Cohort Low | 50 Median (interquartile range [IQR]): 35 (29 to 49) months | France | I–III Adenocarcinomas, squamous cell carcinomas, bronchioloalveolar carcinomas | EGFR-WT EGFR-MUT | NR NR
Scoccianti, 2012^87^ Cohort Medium | 250 Up to 48 months | France, Germany, Ireland, Italy, the Netherlands, Poland, Spain, and the United Kingdom | T1–T4 Primary lung cancers | EGFR-WT EGFR-MUT | NR NR | NR 16%
Tsao, 2011^89^ Cohort Low | 436 NR | Canada and United States | IB–II | EGFR-WT EGFR-MUT | White=44.7% Other=6% Unknown=49% | NR EGFR-MUT: 13.4% EGFR-WT: 86.6%

Abbreviations: EGFR = gene name; IQR = interquartile range; mm = millimeter; MUT = mutation; N = number; NR = not reported; SD = standard deviation; WT = wild-type.

#### EGFR Mutation: Risk of Recurrence

Six cohort studies80,81,84,87–89 (total N=1,870) assessed the prognostic value of this test for RR. Kobayashi81 used recurrence as the outcome; Mak84 looked at LRR and distant recurrence but provided adjusted results only for LRR. Scoccianti87 used time to disease progression as the outcome. Tsao89 used relapse-free survival as the outcome. Kim80 used freedom from recurrence as the outcome. Three80,81,89 of the five studies did not specify whether the outcome was loco–regional or distant or both.

Although the HRs for EGFR mutation suggest a protective effect (i.e., were all <1), none of the findings were statistically significant. Thus, the test for EGFR mutations does not appear to have prognostic value in predicting recurrence in NSCLC (Table 16).

Table 16 Lung cancer: Risk of cancer recurrence/disease-free survival/recurrence-free survival for EGFR

Author, Year, Design, N, Risk of Bias | Adjusted Ratios, (95% CI) p-value Test Positive, Test Negative | Variables Used in Multivariate Model
Kim, 2008^80^ Cohort 71 Medium | Freedom from Recurrence HR: NR, p=NS | Male, age >60 years, smoking+, BAC feature+, ≥Stage IIIA, KRAS+, EFGR−
Kim,2013^88^ Cohort 863 Medium | Freedom from recurrence EGFR NS | BAC, age, smoking, pathologic stage, cell type
Kobayashi, 2008^81^ Cohort 127 Medium | Risk of cancer recurrence: HR: 1.42 (0.38 to 5.29) p=0.60 DFS: HR: 1.55 (0.54 to 4.49) p=0.42 | Age (≥64 vs. <64); sex; smoking status (ever vs. never); CEA level (≥5.0 vs. <5.0); tumor size ≥15 vs. <15); non-BAC component (>50% v. ≤50%); EGFR mutation (yes or no)
Mak, 2011^84^ Cohort 123 Medium | LRR HR: 0.44 (0.19 to 1.00) p=0.05 | EGFR mutation status, stage, use of surgery, chemotherapy use, RT dose, primary tumor size
Soccianti, 2012^87^ Cohort 250 Medium | Time to Disease Progression HR: 0.97 (0.67 to 1.38) p=0.68 | Pathological tumor score, pathological node score
Tsao, 2011^89^ Cohort 436 Low | RFS: HR: 0.83 (0.44 to 1.56) p=0.56 | Sex, age, performance status, stage, histology, smoking status, baseline anemia, resection, serum LDH, p53 mutation status, and immunohistochemistry

Abbreviations: BAC = bronchioloalveolar cancer; CEA = carcinoembryonic antigen; CI = confidence interval; CISH = cytokine-inducible SH2-continaing protein; DFS = disease-free survival; EGFR = gene name; HR = hazard ratio; KRAS = gene name; LDH = lactate dehydrogenase; LRR = loco-regional recurrence; NR = not reported; NS = not statistically significant; p = probability; RFS = recurrence-free survival; RT = radiation therapy.

Using a fixed effects model, our meta-analysis, which included the four studies that reported HRs, found no added prognostic value for the EGFR mutation in predicting risk of recurrence HR: 0.87 95% CI (0.65 to 1.15) (Figure 7).

Figure 7 Prognostic value of EGFR mutation testing for risk of recurrence in lung cancer, meta-analysis of adjusted hazard ratios

Figure 7 is titled "Prognostic Value of EGFR Mutations for Risk of Recurrence in Lung Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 4 studies reporting the adjusted hazard ratio for risk of lung cancer recurrence for patients with EGFR mutations compared with wild type EGFR. The figure is described further in the "EGFR Mutation: Risk of Recurrence" section of the reports as follows, "Using a fixed effects model, our meta-analysis found no added prognostic value for the EGFR mutation in predicting risk of recurrence HR: 0.87 95% CI (0.65, 1.15)."

#### EGFR Mutation: Cancer-Specific Survival

We found no studies meeting our inclusion criteria.

#### EGFR Mutation: Overall Survival

Six studies81,83–85,88,89 representing 1,820 patients reported on the prognostic value of EGFR mutation for this outcome. One of the studies did not report any quantitative measures and therefore did not contribute to our strength of evidence determination. All studies looked at the prognostic value of the test in patients with NSCLC.

None of the included studies found a statistically significant HR for overall survival. The magnitude ranged from 0.6 to 1.6 in studies that reported quantitative measures. The other studies only reported that the result was not statistically significant (Table 17).

Table 17 Lung Cancer: EGFR mutation testing overall survival

Author, Year, Design, Risk of Bias | Adjusted Ratios, (95% CI) p-value Test Positive, Test Negative | Variables Used in Multivariate Model
Kim, 2013^88^ Cohort 863 Medium | EGFR NR p=NS | BAC, Gender, age, pathologic stage, and smoking status
Kobayashi, 2008^81^ Cohort 127 Medium | HR: 1.60 (0.49 to 5.23) p=0.44 | Age (≥64 v. <64); sex; smoking status (ever vs. never); CEA level (≥5.0 vs. <5.0); tumor size (≥15 vs. <15); non-BAC component (>50% vs. ≤50%); EGFR mutation (yes or no)
Liu, 2010^83^ Cohort 164 Medium | HR: 0.53 (95% CI, 0.24 to 1.17), p=NR | Year group, gender, age, pathology, stage, smoking status, CISH, KRAS mutation status, EGFR mutation expression
Mak, 2011^84^ Cohort 123 Medium | HR: NR p=NS | EGFR mutation status, age, stage, PS score, smoking status, use of surgery, chemotherapy use, RT dose, primary tumor size (i.e., all outcomes that were significantly different between groups)
Matsumoto, 2006^85^ Cohort 107 Medium | HR: 1.11 (0.38 to 3.24) p=0.85 | Adjusted by all potential prognostic factors including gender, age, smoking status, tumor stage, tumor size, differentiation, KRAS status
Tsao, 2011^89^ Cohort 436 Low | HR: 0.68 (0.34 to 1.36) p=0.28 | Sex, age, performance status, stage, histology, smoking status, baseline anemia, type of resection, serum lactate dehydrogenase, p53 mutation status, and p53 immunohistochemistry

Abbreviations: BAC = bronchioloalveolar cancer; CI = confidence interval; CISH = cytokine-inducible SH2-continaing protein; EGFR = gene name; HR = hazard ratio; KRAS = gene name; NR = not reported; NS = not statistically significant; OS = overall survival; p = probability; PS = performance status; RT = radiation therapy.

Using a fixed effects model, our meta-analysis, which included the four studies that reported HRs, found no added prognostic value for the EGFR mutation in predicting overall survival HR, 0.77; 95% CI (0.50 to 1.19) (Figure 8).

Figure 8 Prognostic value of EGFR mutation testing for overall survival in lung cancer, meta-analysis of adjusted hazard ratios

Figure 8 is titled "Prognostic Accuracy of EGFR Mutations for Overall Survival in Lung Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 4 studies reporting the adjusted hazard ratio for overall survival for lung cancer patients with EGFR mutations compared with wild type EGFR. The figure is described further in the "EGFR Mutation: Overall Survival" section of the reports as follows, "Using a fixed effects model, our meta-analysis found no added prognostic value for the EGFR mutation in predicting risk of recurrence HR: 0.77, 95% CI (0.50, 1.19)."

#### Characteristics of Included Studies Assessing the Clinical Validity of KRAS Mutation testing

We found six studies79,80,83,86,87,90 that examined the added prognostic value of KRAS mutations on the RR, CSS, and OS in patients with NSCLC. All were cohort studies with sample sizes that ranged from 100 to 250 patients. Studies were conducted in Japan, South Korea, Taiwan, and various European countries. Race/ethnicity was not reported in any of the studies. All studies compared outcomes of patients with KRAS wild-type with those with KRAS mutations. The representation of female patients in the studies ranged from a low of 16 percent to a high of 59 percent. Median length of follow-up was not available in all studies. Length of follow-up ranged from 4 to 14 years.

Populations represented in the studies varied somewhat. The differences were both in cancer stage and cancer type. Three studies included all stages.79,80,87 Two included stages I to III,83,86 and one90 included only stage I (Table 18).

Table 18 Characteristics of included studies: KRAS mutation testing for nonsmall cell lung cancer

Author, Year Study Type Risk of Bias | N Length of followup | Country(ies ) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Guan, 2012^91^ Cohort Medium | 182 Median (all groups): 22.0 months Median (KRAS/WT): 22.7/20.6 months | China | I–IV Primary lung cancer | KRAS-WT KRAS-MUT | NR | Median: 59 37%
Hiramitsu, 2010^79^ Cohort High | 193 Median: 295.1 week | Japan | I–IV Primary lung cancer | KRAS-WT KRAS-MUT | NR | Mean=63 50.3%*
Kim, 2008^80^ Cohort Medium | 71 Mean (SD): 25.3 (11.1) months Range: 2.9 to 47.5 months | Republic of Korea (South Korea) | I–IV | KRAS-WT KRAS-MUT | NR | Median (range)=59.6 (38–85) 59.2%
Liu, 2010^83^ Cohort Medium | 164 Range: 3.9 to 687 weeks | China (Taiwan) | I–IIIA Adenocarcinoma, squamous cell carcinoma, adenosquamous carcinoma | KRAS-WT KRAS-MUT | NR | NR 32.9%
Rouquette, 2012^86^ Cohort Low | 100 Median (IQR): 35 (29 to 49) months | France | I–III Adenocarcinomas, squamous cell carcinomas, bronchioloalveolar carcinomas | KRAS-WT KRAS-MUT | NR | NR 50%
Scoccianti, 2012^87^ Cohort Medium | 250 Up to 48 months | France, Germany, Ireland, Italy, the Netherlands, Poland, Spain, and the United Kingdom | T1–T4 Primary lung cancers | KRAS-WT KRAS-MUT | NR | NR 16%
Woo, 2009^90^ Cohort Medium | 190 Median (range): 35.9 (1.1 to 82.5) months | Japan | IA–IB | KRAS-WT KRAS-MUT | NR | Mean (SD) (range)=67.8 (8.4) (45–85) 48.4%

Abbreviations: IQR = interquartile range; KRAS = gene name; MUT = mutation; N = number; NR = not reported; SD = standard deviation; WT = wild-type.

#### KRAS Mutation: Risk of Recurrence

Four studies80,86,87,90 examining five cohorts(total N=611) rated as low or medium RoB assessed the prognostic value for RR (Table 19). Kim80 and Scoccianti87 studied NSCLC, whereas Woo90 studied the effect of the mutation specifically on stage I adenocarcinomas.

Table 19 Lung cancer: KRAS risk of cancer recurrence/disease-free survival/recurrence-free survival

Author, Year, Design, N, Risk of Bias | Adjusted Ratios, (95% CI) p-value Test Positive, Test Negative | Variables Used in Multivariate Model
Kim, 2008^80^ Cohort 71 Medium | Freedom from recurrence HR: 2.8 (1.060 to 7.391) p=0.038 | Multifactors chosen by step-forward method: male; age >60 years; smoking+; BAC feature+; ≥ Stage IIIA; KRAS+; EGFR−
Rouquette, 2012^86^ Cohort 100 Low | DFS HR: NR, p=NS | EGFR mutation status, KRAS mutation status, HER2 expression, progesterone receptor expression, presence of lymphatic embols, tumor stage III
Scoccianti, 2012^87^ Cohort 250 Medium | Time to Progression HR: 1.19 (0.75 to 1.90) p=0.46 | Pathological tumor score; pathological node
Woo, 2009^90^ Cohort 1A N = 131 Cohort 1B N = 59 Medium | DFS For stage IA: HR: 4.55, (1.61 to 12.82) p=0.004 For Stage IB: HR: 14.99 (1.55–145.21) p=0.019 | Age, tumor size, vessel invasion, Ki-67 expression

Abbreviations: BAC = bronchioloalveolar cancer; CI = confidence interval; CISH = cytokine-inducible SH2-containing protein; EGFR = gene name; HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu; HR = hazard ratio; KRAS = gene name; NR = not reported; OR = odds ratio; p = probability.

Kim80 used freedom from recurrence as the outcome; the publication did not specify whether the recurrence was restricted to loco-regional or distant recurrence. Scoccianti87 used time to disease progression as the outcome. Woo90 also used disease-free recurrence as the outcome and did not specify if this was restricted to loco-regional or distant recurrence. Rouquette86 used disease-free survival as the outcome and defined it as relapse, metastases, or death by any cause, whichever occurred first.

Rouquette86 and Scoccianti87 reported that KRAS mutation did not have added prognostic value. However, Kim80 and Woo90 reported that KRAS is a significant predictor for RR after controlling for other prognostic factors; the HRs range between 2.8 and 4.55.

Using a random effects model, our meta-analysis found added prognostic value of KRAS for risk of recurrence (HR, 2.84; 95% CI, 1.14 to 7.10) (Figure 9).

Figure 9 Prognostic value of KRAS mutation testing for risk of recurrence in lung cancer, meta-analysis of adjusted hazard ratios

Figure 9 is titled "Prognostic Accuracy of KRAS Mutations for Risk of Recurrence in Lung Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 4 hazard ratios (one study had 2 stages that were entered separately) for the risk of lung cancer recurrence for patients with KRAS mutations compared with wild-type KRAS. The figure is described further in the "KRAS Mutation: Risk of Recurrence" section of the report as follows, "Using a random effects model, our meta-analysis found no added prognostic value of KRAS for risk of recurrence (HR 2.84, 95% CI, 1.4, 7.10)."

#### KRAS Mutation: Cancer-Specific Survival

We found no studies meeting our inclusion criteria.

#### KRAS Mutation: Overall Survival

Two studies80,91with 253 patients reported that KRAS testing had added prognostic value for OS (Table 20).

Table 20 Lung cancer: KRAS overall survival

Author, Year, Design, N, Risk of Bias | Adjusted Ratios, (95% CI) p-value Test Positive, Test Negative | Variables Used in Multivariate Model
Kim, 2008^80^ Cohort 71 Medium | KRAS+ HR: 3.339 (1.027 to 10.862) p=0.045 KRAS+ 7.0%^a^ (N=5) KRAS− 93.0%^a^ (N=66) | Multifactors chosen by step-forward method: male; age >60 years; smoking+; BAC feature+; ≥ Stage IIIA; KRAS+
Guan, 2012^91^ Cohort 182 Medium | KRAS(wild/mutation) (N=91/ N=91) HR: 2.69, 95 % CI 1.91–3.80; P< 0.001 | Gender, age, KRAS/EGFR mutation status, pathology, TNM stage, PS, comorbidities, and smoking status

a calculated by abstractor

Abbreviations: BAC = bronchioloalveolar cancer; CI = confidence interval; HR = hazard ratio; KRAS = gene name; N = number; OR = odds ratio; p = probability.

#### Colorectal Cancer—BRAF Mutation

##### Characteristics of Included Studies Assessing the Clinical Validity of BRAFMutation Testing

We included 17 studies92–108 that examined the added prognostic value of BRAF mutations for RR, CSS, and OS in patients with CRC. All were cohort studies. Sample sizes ranged from 69 to 1,680. Median followup ranged from 3 to 8 years. Studies were conducted in Australia, China, various European countries, and the United States.

All studies compared outcomes of patients with BRAF wild-type to those with BRAF V600 mutations. The representation of female patients in the studies ranged from 2 percent to 53.6 percent. Race or ethnicity was not reported in most studies; one reported enrolling 98 percent white patients.102

Populations represented in the studies varied somewhat. The differences were both in cancer stage and the inclusion or exclusion of rectal cancers. Two studies92,109 examined a sample of stage I and stage III colon cancers. Nine93,94,99,102–106,108 included all stages and colon and rectal cancers. Two95,102 included all stages of colon (not rectal) cancers. In the rest, one study96 included both colon and rectal cancers stages I through III, another97 had only stage III colon cancer patients, one study98 included patients with only proximal colon cancer stages I through IV, and two100,107 included stages II and III colon cancer (Table 21).

Table 21 Characteristics of included studies: BRAF mutation testing for colorectal cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Eklof, 2013^108^ Cohort Medium | 197 (NSHDS) 414 (CRUMS) Median (CRUMS): 113 months Median (NSHDS): 102 months | Sweden | I–IV | BRAF-MUT BRAF-WT | NR | NR 43.7% (CRUMS) 56.9% (NSHDS)
Farina-Sarasqueta, 2010^92^ Cohort Low | 364 Stage II median (range): 239.1 (0 to 473.9) weeks Stage III median (range): 200 (8.7 to 578.3) weeks | The Netherlands | II–III | BRAF-WT BRAF-MUT | NR NR | Stage II mean age: 71.5 Stage III mean age: 62.5 45.6%
Kakar, 2008^93^ Cohort High | 69 NR | United States | I–IV | BRAF-WT BRAF-MUT | NR NR | NR 41%
Kalady, 2012^94^ Cohort Medium | 475 NR | United States | I–IV | BRAF-WT BRAF-MUT | NR NR | NR BRAF-WT: 85% BRAF-MUT: 15%
Liou, 2011^95^ Cohort Medium | 314 Median (range) 57 (49 to 82) months | China | I–IV | BRAF-WT BRAF-MUT | NR NR | Median WT 66 Median MUT 75 39%
Lochhead, 2013^105^ Cohort Medium | 1253 Median: 8.2 years, range(3.5–13.1)years | United States | I-IV | BRAF-WT BRAF-MUT | NR | Mean age +/− SD 68.5±8.7 55%:
Maestro, 2007^96^ Cohort Medium | 324 Median (IQR): 43 (27 to 63) months | Spain | Duke’s Stages A–D | BRAF-WT BRAF-MUT | NR NR | Mean (range): 69.6 (30 to 95) 47.9%
Ogino, 2012^97^ Cohort Medium | 506 Median: 91.2 months | United States | III | BRAF-WT BRAF-MUT | NR NR | Median (SD): 59.7 (11.5) 46%
Pai, 2012^98^ Cohort High | 181 Median (range): 52 (0 to 331) weeks | United States | I–IV | KRAS-MUT BRAF-MUT KRAS and BRAF-WT | NR NR | Mean (range): 67 (33 to 98) 47%
Phipps, 2012^99^ Cohort Medium | 1980 Median (range): 7.4 (0.4 to 13.8) years | United States | Stages categorized according to SEER conventions (localized, regional, distant, or unknown) | BRAF-WT BRAF-MUT | NR NR | NR 54.5%
Roth, 2010^100^ Cohort Medium | 1307 Median: 296 weeks | Switzerland, Belgium, Italy, Hungary, Spain, France, and United Kingdom | II–III | BRAF-WT BRAF-MUT | NR NR | NR 42.2%
Roth, 2012^107^ Cohort Medium | 1404 Median: 69 months | Switzerland | II–III | BRAF-MUT BRAF-WT | NR | Median (range): 60 (21–76) 42.8%
Samadder, 2013^106^ Cohort Medium | 563 NR | United States | I–IV | MSS MSI-L/H BRAF-MUT BRAF-WT | NR | Mean (SD): 73.9 (5.92) 100%
Samowitz, 2005^101^ Cohort High | 803 NR | United States | I–IV | BRAF-WT (microsatellite stable tumors) BRAF-MUT (V600E) (microsatellite stable tumors) | NR NR | Range: 30 to 79 45.8%
Shaukat, 2010^102^ Cohort Medium | 194 NR | United States | I–IV | BRAF-WT BRAF-MUT | White: 98% NR | NR 2%
Tie, 2011^103^ Cohort Medium | 525 38.5 months (median recurrence) 12.9 months (median overall survival) | Australia | I–IV | BRAF-WT BRAF-MUT | NR NR | Median 70.5 50%
Zlobec, 2010^104^ Cohort Medium | 404 Median: 234.8 weeks (all patients) Median: 260.9 weeks (CSS) | Switzerland | T1–T4 | BRAF-WT BRAF-MUT | NR NR | Mean (range): 69.5 (40–95) 53.6%

Abbreviations: BRAF = gene name; CSS = cancer-specific survival; IQR = interquartile range; KRAS = gene name; MUT = mutation; NR = not reported; SD = standard deviation; SEER = Surveillance, Epidemiology, and End Results; WT = wild-type.

##### BRAF: Risk of Recurrence

Five cohort studies92,97,100,103,107 rated as low or medium RoB (total N=4,106) examined the prognostic significance of the BRAF mutation for RR (Table 22). The definitions for the outcomes differed a little between the studies. Farina92 defined disease-free survival (DFS) as time to recurrence of disease or distant metastasis; Ogino97 defined DFS as time to disease recurrence or distant metastasis or death from any cause; Roth (2010),100 Roth (2012)107 and Tie103 defined their outcome as recurrence of CRC and did not specify if recurrence includes local and distant.

Table 22 Colorectal cancer: BRAF risk of cancer recurrence/disease-free survival/recurrence-free survival

Author, Year, Design, N Test (Cancer), Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Farina-Sarasqueta, 2010^92^ Cohort 364 Low | DFS HR=0.43 (0.22 to 0.82) p=NR | Differentiation grade, age, sex, tumor location, tumor stage, node stage, KRAS status, BRAF status, and MSI status
Ogino, 2012^97^ Cohort 506 Medium | DFS HR: 1.48 (0.96 to 2.27) p=NR RFS HR: 1.38 (0.88 to 2.16) p=NR | Age, sex, baseline body mass index (BMI), family history of CRC in first-degree relatives, performance status, presence or absence of perforation and/or obstruction at surgery, treatment arm, tumor location, tumor and node stage, KRAS status, MSI status
Roth, 2010^100^ Cohort 1307 Medium | RFS, All subjects HR: 1.30 (0.87 to 1.95) p=0.21 Stage II subjects HR: 1.93 (0.67 to 5.60) p=0.23 Stage III subjects HR: 1.23 (0.79 to 1.92) p=0.35 | Treatment arm, age, sex, grade, tumor site, nodal stage, MSI, KRAS, BRAF mutation status
Roth, 2012^107^ Cohort 1404 Medium | RFS, HR: 1.17 (0.79 to 1.73) p=0.44 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, MSI status, SMAD4 expression, 18qLOH status, and KRAS
Tie, 2011^103^ Cohort 525 Medium | RR HR: 0.89 (0.46 to 1.74) p=0.74 | Age, gender, stage, tumor site, use of adjuvant therapy

Abbreviations: BMI = body mass index; BRAF = gene name; CI = confidence interval; CRC = colorectal cancer; DFS = disease-free survival; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; N = number; NR = not reported; p = probability; RFS = recurrence-free survival; RR = risk of recurrence.

The included studies reported on the prognostic value of testing for BRAF after controlling for certain traditional prognostic factors such as stage, sex, and age. Three of the four studies found no association between BRAF and prognosis in adjusted analyses. Farina92 reported a significant association (HR, 2.32; 95% CI, 1.21 to 4.54) between RR and the BRAF mutation.

Using a random effects model, our meta-analysis found no added prognostic value of BRAF for risk of recurrence (HR, 1.07; 95% CI, 0.76 to 1.52) (Figure 10).

Figure 10 Prognostic value of BRAF mutation testing for risk of recurrence in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 10 is titled, "Prognostic Value of BRAF for Risk of Recurrence in Colorectal Cancer, Meta-analysis of adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 7 studies reporting the adjusted hazard ratio for risk of colorectal cancer recurrence for patients who have BRAF mutations compared with wild type BRAF. The figure is described further in the "BRAF: Risk of Recurrence" section of the report as follows, "Using a random effects model, our meta-analysis found no added prognostic value of BRAF for risk of recurrence (HR 1.07, 95% CI, 0.76 to 1.52)."

#### BRAF for Colorectal Cancer: Cancer-Specific Mortality

Seven studies reporting on eight different cohorts with low or medium RoB (total N=5,409) reported on BRAF mutation and CSS.92,95,96,99,105,106,108 Five out of seven cohorts had statistically significant HRs, suggesting a positive association between mutation and greater risk of cancer-specific death (Table 23). A summary measure was estimated using a fixed effects model. The overall HR for CSS for the patients with wild-type compared with mutated was 1.50, 95% CI (1.26 to 1.77) (Figure 11).

Table 23 Colorectal cancer: BRAF cancer-specific mortality

Author, Year, Design, Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Farina-Sarasqueta, 2010^92^ Cohort 364 Low | HR: 2.12 (1.01 to 4.54) p=0.05 | Differentiation grade, age, sex, tumor location, tumor stage, node stage, KRAS status, BRAF status, and MSI status
Eklof, 2013^108^ Cohort 197 (NSHDS) 414 (CRUMS) Medium | (NSDHS, N = 196) HR: 1.998 (1.165 to 3.426) p=NR (CRUMS, N = 377) HR: 0.94 (0.529 to 1.576) p=NR | Sex, age at diagnosis, stage, tumor site
Liou, 2011^95^ Cohort 314 Medium | HR: 4.41 (1.26 to 15.39) p=0.02 | Age, sex, stage, lymphatic invasion, venous invasion, tumor differentiation, CEA level (>5 vs. ≤5 ng/mL)
Lochhead, 2012^105^ Cohort 1,253 Medium | BRAF-MUT HR:1.64 (1.18 to 2.27) p =0.003 | Age at diagnosis, year of diagnosis, BMI, differentiation grade LINE-1 methylation, stage, KRAS and P1K3CA status
Maestro, 2007^96^ Cohort 324 Medium | HR: 1.62 (0.50 to 5.21) p=0.38 | Age, sex, Duke’s stage, tumor site, differentiation grade, histology, adjuvant chemotherapy, MSI, and BRAF
Phipps, 2012^99^ Cohort 1980 Medium | HR: 1.43 (1.05 to 1.95) p=NR | Age at diagnosis, sex, time from diagnosis to enrollment, SEER stage, MSI status
Samadder, 2013^106^ Cohort 563 Medium | HR: 1.23 (0.78 to 1.94) p=0.38 | Age at diagnosis, anatomic subsite, tumor grade, SEER stage, chemotherapy exposure, and radiation therapy exposure

Abbreviations: BRAF = gene name; CEA = carcinoembryonic antigen; CI = confidence interval; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; ng/mL = nanograms/milliliter; NR = not reported; p = probability; SEER = Surveillance, Epidemiology, and End Results.

Figure 11 Prognostic value of BRAF mutation testing for cancer-specific survival in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 11 is titled "Prognostic Value of BRAF Mutation Testing for Cancer Specific Survival in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot from a meta-analysis of 8 studies reporting the adjusted hazard ratio for cancer-specific survival for colorectal cancer patients who have wild-type BRAF compared with those with BRAF mutations. The figure is described further in the "BRAF for colorectal cancer: Cancer-specific mortality" section of the report as follows, "The overall HR for CSS for the patients with wild-type compared with mutated was 1.50, 955 CI (1.27 to 1.77)."

#### BRAF for Colorectal Cancer: Overall Survival

Eleven studies with twelve cohorts rated as low or medium RoB reported on prognostic value of BRAF for OS in patients with CRC92,94,95,97,99,100,102,103,105–107 (total N=7,610) (Table 24).

Nine out of twelve cohorts reported significant associations between BRAF mutation status and survival. The summary HR for overall survival used a fixed effects model for patients with wild-type compared with those with BRAF mutations of 1.45 (1.3 to 1.62) (Figure 12).

Table 24 Colorectal cancer: BRAF overall survival

Author, Year, Design, Risk of Bias | Adjusted Ratios, (95% CI) p- value | Variables Used in Multivariate Model
Farina-Sarasqueta, 2010^92^ Cohort 364 Low | BRAF HR: 2.22 (1.25 to 4) p<0.05 | Differentiation grade, age, sex, tumor location, tumor stage, node stage, KRAS status, BRAF status, and MSI status
Kalady, 2012^94^ Cohort 475 Medium | HR: 1.79 (1.05 to 3.05) p=0.031 | BRAF mutation, MSI status, TNM stage, sex, age (>55 years), differentiation, proximal tumor site
Liou, 2011^95^ Cohort 314 Medium | HR: 3.91 (1.31 to 11.66) p=0.014 | Age, sex, stage, lymphatic invasion, venous invasion, tumor differentiation, CEA level (>5 vs. ≤5 ng/mL)
Lochhead, 2012^105^ Cohort 1,253 Medium | BRAF-Mut HR: 1.38 (1.07–1.79) p = 0.013 | Age at diagnosis, Year of diagnosis, BMI, differentiation grade LINE-1 methylation, stage, KRAS and P1K3CA status
Ogino, 2012^97^ Cohort 506 Medium | HR: 1.66 (1.05 to 2.63) p=NR | Age, sex, baseline BMI, family history of CRC in first-degree relatives, performance status, presence or absence of perforation and/or obstruction at surgery, treatment arm, tumor location, T and N stage, KRAS status, MSI status
Phipps, 2012^99^ Cohort 1980 Medium | HR: 1.21 (0.96 to1.54) p=NR | Age at diagnosis, sex, time from diagnosis to enrollment, SEER stage, MSI status
Roth, 2010^100^ Cohort 1307 Medium | All subjects HR: 1.78 (1.15 to 2.76) p=0.010 Stage II subjects: HR: 3.83 (1.09 to 13.5) p=0.036 Stage III subjects: HR: 1.67 (1.04 to 2.68) p=0.035 | Treatment arm, age, sex, grade, tumor site, nodal stage, MSI, KRAS, BRAF mutation status
Roth, 2012^107^ Cohort 1404 Medium | HR: 1.56 (1.02 to 2.39) p=0.04 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, MSI status, SMAD4 expression, 18qLOH status, and KRAS
Samadder, 2013^106^ Cohort 563 Medium | HR: 1.22 (0.89 to 1.68) p=0.21 | Age at diagnosis, anatomic subsite, tumor grade, SEER stage, chemotherapy exposure, and radiation therapy exposure
Shaukat, 2010^102^ Cohort 194 Medium | HR: 1.95 (1.18 to 3.20) p=0.008 | Age, tumor grade, TNM (tumor-node-metastasis) stage, and MSI status
Tie, 2011^103^ Cohort 503 Medium | BRAF mutant for Stages I–III HR: 1.24 (0.76 to 2.03) p=0.40 | Age, gender, stage, tumor site, use of adjuvant therapy

Abbreviations: BMI = body mass index; BRAF= gene name; CEA = carcinoembryonic antigen; CI = confidence interval; HR= hazard ratio; KRAS = gene name; MSI = microsatellite instability; NR = not reported; p = probability; SEER = Surveillance, Epidemiology, and End Results; TNM= tumor, node, metastases.

Figure 12 Prognostic value of BRAF mutation testing for overall survival in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 12 is titled "Prognostic Value of BRAF mutations for Overall Survival in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." This figure displays a forest plot showing a meta-analysis of 13 studies reporting hazard ratios for overall survival of colorectal cancer patients with wild-type BRAF compared with those with BRAF mutations. This figure is described further in the "BRAF for Colorectal Cancer: Overall Survival" section of the main report as follows: "Six out of eight studies reported associations between BRAF mutation status and survival. The summary HR for overall survival used a fixed effects model for patients with wild type compared with those with BRAF mutations of 1.45 (1.29 to 1.62)."

#### Colorectal Cancer: KRAS Mutation

##### Characteristics of Included Studies Assessing the Clinical Validity of KRAS Mutation Testing

The genetic test for KRAS mutations described here checks for mutations in codons 12 and 13 in the KRAS gene. We included 14 cohort studies92,95,98,100,103,106–114 that examined the effect of KRAS mutations on the RR, CSS, or OS in patients with CRC (Table 25). Sample sizes ranged from 135 to 1,404. Median followup was between 3 to 12 years. Studies were conducted in Australia, China, various European countries, and the United States.

Table 25 Characteristics of included studies: KRAS mutation testing for colorectal cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Bazan, 2005^109^ Cohort Medium | 160 Median (range): 71 (34 to 115) months | Italy | Duke’s stages A–D | KRAS-WT KRAS-MUT | NR NR | Median (range): 66 (31 to 88) 52.5%
Deschoolmeester, 2010^110^ Cohort Unclear | 164 Median: 242 weeks (overall survival): Median: 232 weeks (disease-free survival) | Belgium | I–IV | KRAS-WT KRAS-MUT | NR NR | Median: 65 +/− 13 48.8%
Eklof, 2013^108^ Cohort Medium | 197 (NSHDS) 414 (CRUMS) Median (CRUMS): 113 months Median (NSHDS): 102 months | Sweden | I–IV | KRAS-MUT KRAS-WT | NR | NR 43.7% (CRUMS) 56.9% (NSHDS)
Farina-Sarasqueta, 2010^92^ Cohort Low | 364 Stage II median (range): 239.1 (0–473.9) weeks Stage III median (range): 200 (8.7–578.3) weeks | The Netherlands | II–III | KRAS-WT KRAS-MUT | NR NR | Stage II mean age: 71.5 Stage III mean age: 62.5 45.6%
Geido, 2002^111^ Cohort Low | 135 Mean (range): 72 (3 to 103) months | Italy | Duke’s Stages A–D Sporadic CRC: proximal (i.e., cecum, ascending and transverse colon sites) and distal (i.e., descending and sigmoid colon and rectum) | KRAS-WT KRAS-MUT KRAS-MUT (G-->A) KRAS-MUT (G-->C/T) | NR NR | Median: 67 44%
Imamura, 2012^112^ Cohort High | 1075 Median (IQR): 611 (433 to 840) weeks | United States | I–IV | KRAS-WT KRAS-MUT codon 12 KRAS-MUT codon 13 | NR NR | Mean (SD): 68.5 (8.7) 55%
Li, 2012^114^ Cohort Medium | 78 Max FU was 43 months; Min was 12 | China | I–IV | KRAS-WT KRAS-MUT | NR | Overall NR: Range: 28–70y 44.9% overall KRAS-WT:74.3% KRAS-MUT:25.7%
Liou, 2011^95^ Cohort Medium | 314 Median (range) 57 (49–82) months | China | I–IV | KRAS-WT KRAS-MUT | NR NR | KRAS-WT mean (SD): 64.8 (12.7) KRAS-MUT mean (SD): 65.7 (13.1) KRAS-WT: 42.6% KRAS-MUT: 57%
Ogino, 2009^113^; Cohort Medium | 508 Median: 323.6 weeks | United States | III | KRAS-WT KRAS-MUT | NR NR | Median (SD): 59.8 (11.5) 46%
Pai, 2012^98^ Cohort High | 181 Median (range): 12 (0 to 76) months | United States | I–IV | KRAS-MUT KRAS WT | NR NR | Mean (range): 67 (33 to 98) 47%
Roth, 2012^107^ Cohort Medium | 1404 Median: 69 months | Switzerland | II–III | KRAS-MUT KRAS-WT | NR | Median (range): 60 (21–76) 42.8%
Roth, 2010^100^ Cohort Medium | 1,299 Median: 296 weeks | Switzerland, Belgium, Italy, Hungary, Spain, France, and United Kingdom | II–III | KRAS-WT KRAS-MUT | NR NR | NR 42.3%
Samadder, 2013^106^ Cohort Medium | 563 NR | United States | I–IV | KRAS-MUT KRAS-WT | NR | Mean (SD) [age at diagnosis]: 73.9 (5.92) 100%
Tie, 2011^103^ Cohort Medium | 510 Median 38.5 months (recurrence) Median 12.9 months (overall survival) | Australia | I–IV | KRAS-WT KRAS-MUT | NR | KRAS-WT median: 70.7 KRAS-MUT median: 70.4 KRAS-WT: 68% KRAS-MUT: 32%

Abbreviations: IQR = interquartile range; KRAS = gene name; MUT = mutation; N = number; NR = not reported; SD = standard deviation; WT = wild-type.

All studies compared outcomes of patients with KRAS wild-type with those who had KRAS mutations. Some also looked at mutations in codon 13 and the mutation from G to C/t and G to A. The representation of female patients in the studies ranged from 42 percent to 55 percent. Race or ethnicity was not reported in any of the studies.

Populations represented in the studies varied somewhat. The differences were both in cancer stage and the inclusion or exclusion of rectal cancers. Five studies103,107–112,114 included all stages and colon and rectal cancers. Among the rest, one95 included all stages of colon (not rectal) cancers, another92 examined a sample of stage II and stage III colon cancers, and Maestro96 included stages I to III and both colon and rectal cancers. Ogino97 had only stage three colon cancer patients, Pai98 studied proximal colon stages I through IV, and Roth100 included stage II and III colon cancer.

#### KRAS for Colorectal Cancer: Risk of Recurrence

Five cohort studies (total N=4,085) rated as low or medium RoB92,100,103,107,113 examined RR as an outcome (Table 26). Farina92 defined DFS as time to recurrence of disease or distant metastasis; Ogino113 defined DFS as time to disease recurrence or distant metastasis or death from any cause; Roth100 did not define their outcome of relapse-free survival but presumably included loco-regional and distant recurrence; and Tie103 defined their outcome as recurrence of CRC, which presumably means loco-regional and distant recurrence.

Table 26 Colorectal cancer: KRAS risk of cancer recurrence/disease-free survival/recurrence-free survival

Author, Year, Design, N, Test (Cancer), Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Farina-Sarasqueta, 2010^92^ Cohort 364 Low | DFS HR: 0.6 (0.38 to 0.97) p=NR | Differentiation grade, age, sex, tumor location, tumor stage, node stage, KRAS status, BRAF status, and MSI status
Ogino, 2009^113^ Cohort 508 Medium | DFS: HR: 0.95 (0.70 to 1.28) p=NR RFS: HR: 0.93 (0.68 to 1.28) p=NR | Age, sex, BMI, tumor location, tumor and node stage, presence or absence of perforation and/or obstruction at diagnosis, performance status, MSI status, and treatment arm
Roth, 2010^100^ Cohort 1,299 Medium | RFS All subjects HR: 1.20 (0.96 to 1.49) p=0.11 Stage II subjects HR: 1.26 (0.75 to 2.13) p=0.38 Stage III subjects HR: 1.21 (0.95 to 1.54) p=0.12 | Treatment arm, age, sex, grade, tumor site, nodal stage, MSI, KRAS, BRAF mutation status
Roth, 2012^107^ Cohort 1404 Medium | RFS HR: 1.05 (0.85 to 1.30) p=0.65 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, MSI status, SMAD4 expression, 18qLOH status, and BRAF
Tie, 2011^103^ Cohort 510 Medium | RR HR: 1.00 (0.68 to 1.48) p=1.00 | Age, gender, tumor site, stage

Abbreviations: BMI = body mass index; BRAF = gene name; CI = confidence interval; DFS = disease-free survival; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; N = number; p = probability; RFS = recurrence-free survival.

The included studies reported on the prognostic value of testing for KRAS after controlling for certain traditional prognostic factors such as stage, sex, and age. Three out of the four studies reported no statistically significant association between KRAS and prognosis in adjusted analyses. Farina reported a significant association between the KRAS wild-type and improved survival.

Our meta-analysis found no significant added prognostic value of KRAS mutation testing for RR in patients with CRC HR, 1.02 (95% CI, 0.91 to 1.14) (Figure 13).

Figure 13 Prognostic value of KRAS mutation testing for risk of recurrence in colorectal cancer, meta–analysis of adjusted hazard ratios

Figure 13 is titled "Prognostic Value of KRAS Mutation Testing for Risk of Recurrence in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot showing a meta-analysis of 6 studies reporting hazard ratios for risk of recurrence for colorectal cancer patients with KRAS mutations compared with those with wild-type KRAS. This figure is described further in the "KRAS for Colorectal Cancer: Risk of Recurrence" section of the main report as follows: "Our meta-analysis found no significant added prognostic value of KRAS mutation testing for RR in patients with CRC (HR: 1.02 (0.91 to 1.14)."

#### KRAS for Colorectal Cancer: Cancer-Specific Mortality

We found two studies ( N = 1,174) that looked at the prognostic effect of KRAS mutation on CSS. Eklof108 examined the effect of KRAS on two different populations; the Colorectal Cancer in Umea Study ( CRUMS) and the Northern Sweden Health Disease Study (NSHDS). They report a significant HR in CRUMS and a nonsignificant HR in the NHSDS. Sammader reports a nonsignificant HR (Table 27).

Our meta-analysis found that KRAS mutation has a significant prognostic effect on CSS with a HR of 1.30 (95% CI, 1.02 to 1.66) (Figure 14).

Table 27 Colorectal cancer: KRAS cancer-specific survival

Author, Year, Design, Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Eklof, 2013^108^ Cohort 197 (NSHDS) 414 (CRUMS) Medium | (NSDHS, N = 179) HR: 0.798 (0.443 to 1.438) p=NR (CRUMS, N = 378) HR: 1.485 (1.023 to 2.15 Colorectal Cancer in Umeå Study (CRUMS)5) p=NR | Sex, age at diagnosis, stage, tumor site
Samadder, 2013^106^ Cohort 563 Medium | HR: 1.40 (0.95 to 2.06) p=.08 | Age at diagnosis, anatomic subsite, tumor grade, SEER stage, chemotherapy exposure, and radiation therapy exposure

Abbreviations: CRUMS = Colorectal Cancer in Umea Study; HR = hazard ratio; KRAS = gene name; N = number; p = probability. NSHDS= Northern Sweden Health Disease Study

Figure 14 Prognostic value of KRAS mutation testing for CSS in colorectal cancer, meta–analysis of adjusted hazard ratios

Figure 14 is titled "Prognostic Value of KRAS Mutation Testing for Cancer Specific Survival in Colorectal Cancer, Meta–Analysis of Adjusted Hazard Ratios." The figure displays a forest plot showing a meta-analysis of 3 studies reporting hazard ratios for cancer-specific survival for colorectal cancer patients with KRAS mutations compared with those with wild-type KRAS. This figure is described further in the "KRAS for Colorectal Cancer: Risk of Recurrence" section of the main report as follows: "Our meta-analysis found that KRAS mutation has a significant prognostic effect on CSS with a HR of 1.30 (95% CI, 1.02 to 1.66)."

#### KRAS for Colorectal Cancer: Overall Survival

Ten cohort studies with low or medium RoB92,95,100,103,106,107,109,111,113,114 (total N=5,328) examined overall survival as an outcome (Table 28). The included studies reported on the prognostic value of testing for KRAS after controlling for certain traditional prognostic factors such as stage, sex, and age. Six out of seven studies reported no statistically significant association between KRAS mutation status and OS in adjusted analyses. Bazan and Geido109,111 reported significant associations between KRAS gene mutation status and survival.

Our meta-analysis found no significant added prognostic value of KRAS mutation testing for OS in patients with CRC HR: 1.22 (0.95, 1.55) (Figure 15).

Table 28 Colorectal cancer: KRAS overall survival

Author, Year, Design, Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Bazan, 2005^109^ Cohort MSI (colorectal) Medium | HR: 1.86 (1.10 to 3.17) p<0.05 | Duke’s stage, surgical resection, DNA-aneuploidy, high SPF
Farina-Sarasqueta, 2010^92^ Cohort 364 Low | HR = 0.83 (0.51 to 1.35) p=NR | Differentiation grade, age, sex, tumor location, T stage, nodal stage, KRAS status, BRAF status, and MSI status
Geido, 2002^111^ Cohort 135 Low | Overall RR: 2.57 (1.37 to 4.82) p=0.003 G-A transition mutation subtype RR: 2.29 (1.12 to 4.66) p=0.02 G-C/T transversion mutation subtype RR: 3.34 (1.34 to 8.36) p=0.009 | Model #1 (used to calculate RR of overall KRAS mutation): age, site, Duke’s stages B and C, DNA ploidy, wild-type vs. mutated KRAS-2 status Model #2 (used to calculate RRs of G-->A and G-->C/T KRAS mutations): Same as Model #1, but with KRAS mutations subdivided into two specific types named above
Li, 2012^114^ Cohort 78 Medium | KRAS mutation RR: 4.552 (1.522 – 13.610) p=0.007 | Sex, KRAS mutation, age, growth pattern, location of tumor, tumor differentiation, lymph node metastasis, liver metastasis, TNM stage
Liou, 2011^95^ Cohort 314 Medium | HR: 1.61 (0.91 to 2.84) p=0.101 | Age, sex, stage, use of adjuvant chemotherapy
Ogino, 2009^113^ Cohort 508 Medium | HR: 0.86 (0.60 to 1.23) p=NR | Age, sex, BMI, tumor location, tumor and node stage, presence or absence of perforation and/or obstruction at diagnosis, performance status, MSI status, and treatment arm
Roth, 2010^100^ Cohort 1,299 Medium | All subjects: HR: 1.29 (0.99 to 1.67) p=0.060 Stage II subjects: HR: 1.51 (0.79 to 2.90) p=0.21 Stage III subjects: HR: 1.28 (0.97 to 1.71) p=0.086 | Treatment arm, age, sex, grade, tumor site, nodal stage, MSI, KRAS, BRAF mutation status
Roth, 2012^107^ Cohort 1,404 Medium | HR: 1.10 (0.86 to 1.42) p=0.45 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, MSI status, SMAD4 expression, 18qLOH status, and BRAF
Samadder, 2013^106^ Cohort 563 Medium | HR: 1.05 (0.80 to 1.38) p=0.70 | Age at diagnosis, anatomic subsite, tumor grade, SEER stage, chemotherapy exposure, and radiation therapy exposure
Tie, 2011^103^ Cohort 503 Medium | HR: 0.86 (0.61 to 1.22) p=NR | Age, gender, tumor site, stage

Abbreviations: BMI = body mass index; BRAF = gene name; CI = confidence interval; DNA = deoxyribonucleic acid; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; NR = not reported; RR = relative risk; SPF = S-phase Fraction.

Figure 15 Prognostic value of KRAS mutation testing for overall survival in colorectal cancer, meta–analysis of adjusted hazard ratios

Figure 15 is titled "Prognostic Value of KRAS Mutation Testing for Overall Survival in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." The figure displays a forest plot showing a meta-analysis of 10 studies reporting hazard ratios for overall survival for colorectal cancer patients with KRAS mutations compared with those with wild-type KRAS. This figure is described further in the "KRAS for Colorectal Cancer: Overall Survival" section of the main report as follows: "Our meta-analysis found no significant added prognostic value of KRAS mutation testing for OS in patients with CRC (HR: 1.22 (0.95 to 1.55)."

#### Colorectal Cancer: Microsatellite Instability (MSI)

##### Characteristics of Included Studies Assessing the Clinical Validity of MSI

The test for MSI described here uses the five reference microsatellite markers D5S345, D2S123, BAT25, BAT26, and D17S250 (Bethesda markers) to establish microsatellite instability. We included 17 cohort studies96,103–107,115–125 that examined the added prognostic value of MSI for RR, CSS, or OS in patients with CRC (Table 29). Sample sizes ranged from 55 to 1,175. Median follow up ranged from 3 to 14 years. Studies were conducted in Australia, China, various European countries, Taiwan, and the United States.

Table 29 Characteristics of included studies: MSI for colorectal cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Chang, 2006^115^ Cohort Medium | 213 Median (range): 208.8 (17.4 to 334.8) weeks | China (Taiwan) | I–IV | MSI-H MSS | NR NR | Median (range): 67.6 (23 to 86)
Donada, 2011^116^ Cohort Low | 55 Median: 396.72 weeks, 25th–75th percentile=193.1 weeks to 443.5 weeks | Italy | II–III | MSI-H Non-MSI-H | NR NR | Mean (SD) (range): 62.9 (9.1) (35 to 79)
Guibodoni, 2001^117^ Cohort Medium | 109 Median Recurrence: 74 (50 to 120) months Overall survival: 78 (46 to 120) months | Italy | II–III | MSI-H MSS/MSI-L | NR NR | NR 58.7%
Gyrfe, 2000^118^ Cohort Medium | 587 Mean (SD): 7.2 (0.1) years | United States | T1–T4 | MSI MSS | NR NR | Mean (SD): 43.1 (0.3) 50%
Hong, 2012^119^ Cohort Medium | 1,125 Median: 42 months | South Korea | I–IV | MSI MSS | NR NR | Median (range): 61 (25 to 92) 3.6%
Jensen, 2009^120^ Cohort Medium | 311 Median (range): 6.1 (4.1 to 11.3) years | Denmark | II–IV | MSI MSS | NR NR | NR 48.8%
Kim, 2007^121^ Cohort Low | 542 Censored at 5 years | United States | Duke’s Stages B or C | MSI-H MSS/MSI-L | NR NR | NR NR
Lin, 2012^122^ Cohort Medium | 709 Median (range): 204.9 (4 to 796) weeks | China | I–III | MSI-H MSS/MSI-L | NR NR | Mean (SD): 68.8 (11.5) 32.4%
Lochhead, 2012^105^ Cohort Medium | 1,253 Median: 8.2 years, range (3.5–13.1) years | United States | I–IV | MSI-H MSS | NR NR | NR NR
Maestro, 2007^96^ Cohort Medium | 324 Median (IQR): 43 (27–63) months | Spain | Duke’s Stages A–D | MSS MSI-L MSI-H | NR NR | Mean (range): 69.6 (30 to 95)
Roth, 2012^107^ Cohort Medium | 1,404 Median: 69 months | Switzerland | II–III | MSI-H MS-L/S | NR | Median (range): 60 (21–76) 42.8%
Samadder, 2013^106^ Cohort Medium | 563 Mean (SD) 73.9 (5.92) | United States | Grade I–IV | MSS MSI-L MSI-H | NR NR NR | NR NR NR
Shia, 2008^123^ Cohort High | 130 Median (range): 98 (12 to 168) months | United States | I–IV | MSI-H Non-MSI-H | NR NR | Median (range): 65.5 (31 to 85) 47.7%
Soreide, 2009^124^ Cohort Medium | 186 Range: 291.45 to 495.9 weeks | Norway | I–III | MSS MSI-H | NR NR | Median (IQR): 67 (59 to 73)
Tie, 2011^103^ Cohort Medium | 503 Recurrence: 38.5 months Cancer specific survival: 12.9 months | Australia | I–IV | MSI MSS | NR NR | MSI median: 75.8 MSS median: 69.4 MSI: 15% MSS: 85%
Yoon, 2011^125^ Cohort Low | 2,028 43 (1 to 85) months | Korea | II–III | MSI-H MSI-L MSS | NR NR | Mean (SD): 56.7 (12) MSI-H: 10% MSI-L: NR MSS: 90%
Zlobec, 2010^104^ Cohort Medium | 404 Median: 234.8 weeks (all patients) Median: 260.9 weeks (cancer-specific survival) | Switzerland | T1–T4 | MSI-H MSS/MSI-L | NR NR | Mean (range): 69.5 (40 to 95) 53.6%

Abbreviations: IQR = interquartile range; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSS = microsatellite stability; N = number; NR = not reported; SD = standard deviation; WT = wild-type.

All studies compared outcomes of patients with MSI-H with those with MSS/MSI-L. The representation of female patients in the studies where sex is reported ranged from 3.6 percent to 53 percent. Race or ethnicity was not reported in any of the studies.

There were some differences in the populations examined in the different publications. The differences were with respect to stage and whether rectal cancers were included. Eight studies103–106,115,118,119,123 included patients with colon and rectal cancer at all stages. Four studies96,107,121,124 included patients with stage II or III colon or rectal cancers. Guidoboni117 examined a sample of patients with stage I or II proximal colon cancer only; Jensen120 included patients with stages II, III, and IV colon and rectal cancer; Lin122 had a sample of only stage III colon cancer; and Yoon125 included patients with colon and rectal cancer in stages I through III.

#### MSI for Colorectal Cancer: Risk of Recurrence

Ten cohort studies with low or medium RoB (total N=7,130)103,107,115,117,119–122,124,125 examined RR as an outcome (Table 30). Several studies103,115,117,122,125 had DFS or recurrence as an outcome but did not specify whether they were looking at loco-regional or distant recurrence. Hong119 defined DFS as disease recurrence or progression; Jensen120 looked at recurrence-free survival, which was defined as relapse of primary disease or death; Kim121 had RFS as an outcome, which they defined as time to first occurrence of a tumor recurrence; and Soreido124 looked at any recurrence and separately at loco-regional and distant metastasis.

Table 30 Colorectal cancer: MSI risk of recurrence

Author, Year, Design, N, Test (Cancer), Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Chang, 2006^115^ Cohort 213 Medium | 4 year DFS MSI-H vs. MSS HR: 0.49 (0.18 to 1.38) p=0.179 | TNM stage, P53 mutation, CEA level, differentiation, MSI, location
Guidoboni, 2001^117^ Cohort MSI (colorectal) 109 Medium | DFS HR: 0.32 (0.15 to 0.72) p=0.002 | Sex, age as continuous, TNM stage
Hong, 2012^119^ Cohort 1,125 Medium | DFS Overall HR: 0.57 (0.32 to 0.96) p=0.034 Colon HR: 0.61 (0.33 to 1.10) p=0.100 Rectum HR: 0.48 (0.12 to1.97) p=0.311 | Stage, sex, age
Jensen, 2009^120^ Cohort 311 Medium | RR HR: 0.3 (0.2 to 0.7) p=0.0007 | Thymidylate synthase, dihydropyrimidine, gender, age, stage, differentiation, peripheral invasion, vascular invasion, perforation ileus
Kim, 2007^121^ Cohort 542 Low | RR Overall: RR: 0.68 (0.42 to 1.09) p=0.1 RR Untreated group: HR: 0.77 (0.40 to 1.48) p=NR RR Treated group: HR: 0.60 (0.30 to 1.19) p=NR | Treatment and MSI/treatment interaction, age, sex, stage, tumor site
Lin, 2012^122^ Cohort 709 Medium | DFS HR: 0.982 (0.425 to 2.268) p=0.965 | Age, gender, stage, differentiation
Roth, 2012^107^ Cohort 1404 Medium | RFS MSI-H vs. MS-L/S HR: 0.54 (0.37 to 0.81) p=0.003 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, SMAD4 expression, 18qLOH status, BRAF, and KRAS
Soreide, 2009^124^ Cohort 186 Medium | LRR MSI adjusted for both age and sex OR: 2.5 (1.0 to 6.1) p=0.047 MSI adjusted for tumor location OR: 3.1 (1.1 to 8.8) p=0.026 Any recurrence OR 1.2 (0.6 to 2.4) p=0.64 | Age, sex, MSI and variables that had p-values <0.1 on univariate analysis
Tie, 2011^103^ Cohort 503 Medium | DFS HR: 0.79 (0.47 to 1.32) p=0.36 | Age, gender, tumor site, stage
Yoon, 2011^125^ Cohort 2,028 Low | DFS MSI-H: HR: 0.48 (0.28 to 0.82) p=0.007 | Age, location, gender, CEA, node, distant metastases, histology, lymphovascular invasion, growth type, adjuvant

Abbreviations: CEA = carcinoembryonic antigen; CI = confidence interval; DFS = disease-free survival; HR = hazard ratio; LRR = loco-regional recurrence; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSI-L = microsatellite instability low; MSS = microsatellite stability; N = number; NR = not reported; OR = odds ratio; p = probability; RR = relative risk; TNM = tumor, node, metastases.

The included studies reported on the prognostic value of testing for MSI after controlling for certain traditional prognostic factors such as stage, sex, and age. All but two studies reported point estimates, suggesting an association between MSI-H and lower RR. Four out of nine studies reported statistically significant associations between MSI and RR in adjusted analyses—finding that MSI-H was associated with better prognosis. Our meta-analysis found a lower RR for the patients with MSI-H compared with those with MSS (HR, 0.60; 95% CI, 0.50 to 0.72) (Figure 16).

Figure 16 Prognostic value of microsatellite instability for risk of recurrence in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 16 is titled "Prognostic Value of Microsatellite Instability for Risk of Recurrence in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." This figure displays a forest plot showing a meta-analysis of 10 studies reporting hazard ratios for risk of recurrence for colorectal cancer patients with microsatellite instability compared with microsatellite stability. This figure is described further in the "MSI for Colorectal Cancer: Risk of Recurrence" section of the main report as follows: "Our meta-analysis found a lower RR for the patients with MSI-H compared with those with MSS (HR 0.60; 95% CI, 0.50 to 0.72)."

#### MSI for Colorectal Cancer: Cancer-Specific Survival

Six cohort studies rated as medium RoB96,104–106,122,124 (total N =3,439) reported on CSS as an outcome (Table 31).

Table 31 Colorectal cancer: MSI cancer-specific mortality

Author, Year, Design, N, Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Lin, 2012^122^ Cohort 709 Medium | HR: 0.891 (0.363 to 2.183) p=0.8 | Age, sex, stage, differentiation, MSI status
Lochhead, 2013^105^ Cohort 1253 Medium | MSI-H vs. MSS HR: 0.28 (0.17-0.46) p<0.001 | Age, year of diagnosis, BMI, tumor differentiation LINE-1 methylation),disease stage. KRAS and P1K3CA status
Maestro, 2007^96^ Cohort 324 Medium | MSI-L vs. MSS HR: 0.72 (0.29 to 1.80) p=NR MSI-H vs. MSS HR: 0.33 (0.12 to 0.92) p=NR Any MSI vs. MSS: p=0.036 | Age, sex, Duke’s stage, tumor site, differentiation grade, histology, adjuvant chemotherapy, MSI, and BRAF
Samadder, 2013^106^ 2013 Cohort 563 Medium | MSI –L HR: 0.98 (0.65–1.49) p=.08 MSI-H HR: 0.54 (0.30–0.98) p=.08 | Age at diagnosis, anatomic subsite, tumor grade, SEER stage, chemotherapy exposure and radiation therapy exposure
Soreide, 2009^124^ Cohort 186 Medium | HR: NR (NR) p=0.722 | Age, sex, MSI status, and variables that had p-values <0.1 on univariate analysis
Zlobec, 2010^104^ Cohort 404 Medium | Right-sided location MSI-H HR: 0.41 (0.2 to 0.8) p=0.015 Left-sided location MSI-H HR: 1.16 (0.6 to 2.1) p=0.622 | pT stage, pN stage, vascular invasion and MSI in right- and left-sided CRC

Abbreviations: BRAF = gene name; CI = confidence interval; CRC = colorectal cancer; HR = hazard ratio; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSI-L = microsatellite instability low; MSS = microsatellite stability; NR = not reported; p = probability; pN = pathological node score; pT = pathological tumor score.

The included studies reported on the prognostic value of testing for MSI after controlling for certain traditional prognostic factors such as stage, sex, and age. Two of the four studies reported a statistically significant association between MSI and prognosis of CSS in adjusted analyses. Zlobec104 reported a positive association (HR 0.41 [0.2 to 0.8]) between MSI-H for right-sided tumors for CSS. Maestro96 reported a significant HR association between MSI-H and CSS (HR 0.33 [0.12, 0.92]). Our meta-analysis found an overall HR for CSS for patients with MSI-H tumors compared with MSS tumors of 0.63; 95% CI, (0.51 to 0.79) (Figure 17).

Figure 17 Prognostic value of microsatellite instability for cancer specific survival in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 17 is titled "Prognostic Value of Microsatellite Instability for Cancer Specific Survival in Colorectal Cancer, Meta-Analysis of Adjusted Hazard Ratios." This figure displays a forest plot showing a meta-analysis of 7 studies reporting hazard ratios for cancer-specific survival for colorectal cancer patients with microsatellite instability compared with microsatellite stability. This figure is described further in the "MSI for Colorectal Cancer: Cancer-Specific Survival" section of the main report as follows: "Our meta-analysis found an overall HR for CSS for patients with MSI-H tumors compared with MSS tumors of 0.65; 95% CI (0.51 to 0.82)."

#### MSI for Colorectal Cancer: Overall Survival

Twelve cohort studies103,105,107,115–122,125 (total N =8,839) rated as low or medium RoB examined overall survival (Table 32). Populations examined in the different publications varied somewhat.

The included studies reported on the prognostic value of testing for MSI after controlling for certain traditional prognostic factors such as stage, sex, and age. Four out of 10 studies reported a statistically significant association between MSI and prognosis for OS in adjusted analyses. All 4 found that MSI-H is a good prognostic marker for OS.

Our meta-analysis found an overall HR for OS for patients with MSI-H compared with MSS of 0.57; 95% CI (0.43 to 0.77) (Figure 18).

Table 32 Colorectal cancer: Overall survival with MSI

Author, Year, Design, N Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Chang, 2006^115^ Cohort 213 Medium | 4-year OS HR: NR MSI-H vs. MSS: p=0.858 | TNM (I, II, III, IV), p53 mutation (yes vs. no), CEA level 2 (high vs. low), grade of differentiation (poor vs. well/moderate), MSI status (MSI-H vs. MSS), location (right, left, rectum)
Donada, 2011^116^ Cohort 55 Low | MSI-H vs. non-MSI-H HR: 1.34 (0.22 to 8.05) p=0.75 | Age, sex, tumor location (left-transverse-right), stage (III vs. II), grading (G3-G2-G1), TS expression (high vs. low), TP expression (high vs. low), DPD expression (high vs. low), MSI status (MSI-H vs. non-MSI-H)
Kim, 2007^121^ Cohort 542 Low | MSI-H vs. MSS/MSI-L Stratified by treatment RR=0.91 (0.59, 1.4) Treated group HR=1.02 (0.56 to 1.85) Untreated group HR=0.82 (0.44 to 1.51) | Stratified by treatment: surgery alone vs. surgery + chemotherapy Age, sex, stage, tumor site
Guibodoni, 2001^117^ Cohort 109 Medium | HR: 0.31 (0.14 to 0.68) p=NR | Sex, age, TNM stage
Gyrfe, 2000^118^ Cohort 587 Medium | MSI vs. MSS HR: 0.45 (0.30 to 0.68) p<0.0001 | Lymph-node metastases, microsatellite status (MSS, MSI); tumor invasion (T1-4); distant-organ metastases—microsatellite status (MSS, MSI); tumor invasion (T1–4)
Hong, 2012^119^ Cohort 1125 Medium | Overall 0.7 (0.35 to 1.37) p=0.292 Colon 0.62 (0.29 to 1.4) Rectum 1.07 (0.26 to 1.4) | Stage, sex, age
Jensen, 2009^120^ Cohort 311 Medium | HR: 0.4 (0.2 to 0.9) p=0.02 | Microsatellite instability, thymidylate synthase , dihydropyrimidine dehydrogenase , sex, age, stage, differentiation, perineural invasion, vascular invasion, perforation, ileus
Lin, 2012^122^ Cohort 709 Medium | HR: 0.459 (0.241 to 0.872) p=0.017 | Age, sex, stage, differentiation (well to moderate vs. poor to undifferentiated), MSI status (MSI-H vs. MSI L/S)
Lochhead, 2013^105^ Cohort 2,012 Medium | MSI-high vs. MSS HR: 0.60 (0.45-0.80) p<0.001 | Age, year of diagnosis, BMI, tumor differentiation LINE-1 methylation, stage, KRAS and P1K3CA status
Roth, 2012^107^ Cohort 1404 Medium | HR: 0.43 (0.27 to 0.70) p=0.001 | Age, sex, grade, stage, number of examined lymph nodes, site, treatment group, SMAD4 expression, 18qLOH status, BRAF, and KRAS
Tie, 2011^103^ Cohort 503 Medium | HR: 0.98 (0.65 to 1.47) p=0.92 | Age, gender, tumor site, stage
Yoon, 2011^125^ Cohort 2028 Low | HR: 0.65 (0.39 to1.10) p=0.11 | Age, gender, location, MSI status, CEA, lymph node metastasis, distant metastasis, lymphovascular invasion, histology, adjuvant chemotherapy

Abbreviations: CEA = carcinoembryonic antigen; CI = confidence interval; DPD = dihydropyrimidine dehydrogenase; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSI-L = microsatellite instability low; MSI-L/S = microsatellite instability low or stable; MSS = microsatellite stability; N = number; p = probability; RR = relative risk; TNM = tumor, node, metastases; TP = thymidine phosphorylase; vs. = versus.

Figure 18 Prognostic value of microsatellite instability for overall survival in colorectal cancer, meta-analysis of adjusted hazard ratios

Figure 18 is titled "Prognostic Value of Microsatellite Instability for Overall Survival in Colorectal Cancer, Meta-analysis of Adjusted Hazard Ratios." This figure displays a forest plot showing a meta-analysis of 11 studies reporting hazard ratios for overall survival of colorectal cancer patients with microsatellite instability versus microsatellite stability. This figure is described further in the "MSI for Colorectal Cancer: Overall Survival" section of the main report as follows: "Our meta-analysis found an overall HR for OS for patients with MSI-H compared with MSS of 0.57; 95% CI, (0.43 to 0.77)."

#### Colorectal Cancer: Oncotype DX

##### Characteristics of Included Studies Assessing the Clinical Validity of Oncotype DX Colon

We included one cohort study126 that examined the added prognostic value of Oncotype DX Colon for RR, CSS, or OS in patients with CRC (Table 33).

Table 33 Characteristics of included studies: Oncotype DX for colorectal cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age years) % Female
Venook 2013^126^ Cohort Medium | 690 NR | United States | II | Recurrent patients Nonrecurrent patients | White: 92% NR | NR 41.9%

Abbreviations: N = number; NR = not reported.

##### Oncotype DX: Risk of Recurrence

One included cohort study rated as medium RoB (N=690) reported this outcome.126 The study examined a 12-gene RS as the outcome in stage II CRC patients who were part of the CALGB trial. All patients with recurrence and a random sample of patients with no recurrence were included in the study.

The study reported that the RS from Oncotype DX (treated as a continuous variable) was a significant predictor (HR 1.68; 95% CI, 1.18 to 2.39) after controlling for standard prognostic markers (Table 34).

Table 34 Colorectal cancer: Oncotype DX risk of cancer recurrence/disease-free survival/recurrence-free survival

Author, Year, Design, N, Test (Cancer), Risk of Bias | Adjusted Ratios, (95% CI) p-value | Variables Used in Multivariate Model
Venook 2013^126^ Cohort 690 Medium | RS: HR: 68 (1.18 to 2.38) p=0.004 | MMR, tumor state, number of nodes examined, grade , LVI, RS

Abbreviations: CI = confidence interval; HR = hazard ratio; LVI = lymphovascular invasion; MMR = mismatch repair; N = number; p = probability; RS = risk score.

##### Oncotype DX: Cancer-Specific Mortality

We found no studies meeting our inclusion criteria.

##### Oncotype DX: Overall Survival

We found no studies meeting our inclusion criteria.

#### Bladder Cancer: UroVysion

##### Characteristics of Included Studies Assessing the Clinical Validity of UroVysion

UroVysion is a fluorescence in situ hybridization (FISH) test of exfoliated urothelial cells that has been shown to be sensitive in terms of diagnosing urothelial cancer. It was designed as a diagnostic and not a prognostic test. In this report the test is being evaluated for its prognostic value with respect to predicting recurrence.

We included 3 studies127–129 that examined the added prognostic value of UroVysion for RR, CSS, or OS in patients with bladder cancer (Table 35). Sample sizes ranged from 42 to 138. Studies were conducted in the United States and Switzerland. Race or ethnicity was not reported in any of the studies. One study was rated as high RoB and was not included in our main data synthesis.129

Table 35 Characteristics of included studies: UroVysion for urinary bladder cancer

Author, Year Study Type Risk of Bias | N Length of Followup | Country(ies) | Disease Stage(s) Other Tumor/ Disease Characteristics | Study Groups | Race Ethnicity | Overall Age (years) % Female
Kamat, 2012^127^ Cohort Low | 126 | United States | TA or T1 Nonmuscle invasive bladder cancer (primary or recurrent) | UroVysion+ UroVysion− | NR NR | Median: 67.5 24%
Whitson, 2009^128^ Cohort Low | 42 Median (range): 91.3 (21.7 to 230.5) weeks | United States | T1 High-risk superficial bladder tumor | UroVysion+ UroVysion− | NR NR | Median (range): 68 (41 to 97) NR
Zellweger, 2006^129^ Cohort High | 138 Median (range): 19.2 (4 to 52) months | Switzerland | Stage pTa to pT3; 9 tumors without information on stage were also included | UroVysion+ UroVysion− | NR NR | Median (range): 68.5 (33.4 to 92.5) 15.9%

Abbreviations = N = number; NR = not reported.

##### UroVysion: Risk of recurrence

Two cohort studies (total N = 168) reported on UroVysion and RR. Whitson128 retrospectively studied patients who underwent intravesical therapy (IVT), and Kamat127 prospectively enrolled patients who were scheduled to undergo IVT. Both studies reported that the test is a significant predictor after controlling for traditional prognostic factors (Table 36).

Table 36 Key Question 3: Bladder cancer: UroVysion risk of cancer recurrence/disease-free survival/recurrence-free survival

Author, Year, Design, N, Risk of Bias | Adjusted Ratio (95% CI), p-value | Variables Used in Multivariate Model
Kamat, 2012^127^ Cohort 126 Low | HR: NR p<0.01 | Stage, grade, history of prior tumors, concomitant CIS, use of postoperative mitomycin
Whitson, 2009^128^ Cohort 42 Low | Multivariate HR: 6.7 (2.1 to 22.1) p<0.01 | Age, smoking, radiotherapy, diabetes mellitus, hypertension, hyperlipidemia, CRI, immunosuppression, recurrence rate, whether the tumor was primary or recurrent, multiple tumors, tumor >3 cm, stage T1, high grade, CIS, EORTC score >6, positive cytology, and positive UroVysion

Abbreviations: CI = confidence interval; CIS = carcinoma in situ; cm = centimeter; CRI = chronic renal insufficiency; EORTC = European Organization for Research and Treatment of Cancer; HR = hazard ratio; N = number; p = probability.

##### UroVysion Cancer-Specific Survival

We found no studies meeting our inclusion criteria.

##### UroVysion Overall Survival

We found no studies meeting our inclusion criteria.

### Key Question 4a Influence on Physician Decision

We identified studies evaluating the influence of molecular pathology tests for RR on treatment decisionmaking for three of the tests of interest, the Oncotype DX and MammaPrint assays for breast cancer, and Oncotype DX Colon. For Oncotype DX Colon, none of the included studies were rated as low or medium RoB. For Oncotype DX Breast and MammaPrint, the studies available for review included a mix of prospective and retrospective cohort studies and uncontrolled trial designs, with a larger body of literature examining the use of Oncotype DX than MammaPrint. No studies examined the effect of the two assays compared with each other.

#### Characteristics of Included Studies Assessing Oncotype DX Breast and Treatment Decisions

For Oncotype DX Breast, we included six cohort studies (total N=990 patients) and ten uncontrolled trials (total N=1,261 patients) rated as low or medium RoB (Table 37). One additional uncontrolled trial130,131 was excluded from our main analysis because of an unclear RoB rating and is not included in this summary. Most of the studies were performed at single academic centers or in multicenter studies in the United States, but studies performed at centers in Europe, Canada, Australia, Mexico, Japan and Israel were also found. The studies uniformly examined cohorts with hormone-receptor positive breast cancer, and most were limited to women with node-negative cancers. The mean age of patients in the studies varied from 48 to 61 years.

Table 37 Characteristics of included studies: Oncotype DX Breast and treatment decisions

Author, Year Test (Cancer Type) Risk of Bias | N Study Type | Country(ies) | Disease Stage(s) Other Tumor/Disease Characteristics | Overall Age (years) % Female
Ademuyiwa, 2011^132^ Oncotype DX (breast) Medium | 276 patients 2 oncologists Pre-post-test design and uncontrolled trial | United States | Node negative, ER+, HER2/neu− | Median: 55; Mean (range): 54.8 (29 to 82) 100%
Albanell, 2011^133^ Oncotype DX (breast) Low | 107 Uncontrolled trial | Spain | Node negative, ER+, HER2− | NR 100%
Bargallo, 2012^134^ Oncotype DX (breast) Medium | 96^a^ Uncontrolled trial | Mexico | ER+, HER2−, stage I-IIIa, node-negative or –positive (1–3 nodes) | NR 100%
Davidson, 2013^135^ Oncotype DX (breast) Medium | 150 Uncontrolled trial | Canada | I–II ER+, HER2−, node negative | Mean (range): 53 (23 to 78) 100%
de Boer, 2013^136^ Oncotype DX (breast) Medium | 151 Uncontrolled trial | Australia | Early stage, T1 – T3 Unifocal ER+/−, PR+/−, HER2− , node negative or node positive (1–3 positive nodes, including micrometastases and isolated tumor cells) | Mean: 56.2 100%
Eiermann, 2013^137^ Oncotype DX (breast) Low | 366 Cohort | Germany | Early breast cancer ER+, HER2−, node negative or histologically verified lymph node metastases in up to three lymph nodes | Mean: 56 100%
Geffen, 2011^138^ Oncotype DX (breast) Medium | 135 Cohort | Israel | I–II ER+ or ER−, PR+ or PR−, HER2+ or HER− | Median 58 (33–75) years 97.8%
Gligorov, 2012^130^ Oncotype DX (breast) Unclear | 92 patients NR oncologists Uncontrolled trial | France | ER+, HER2−, node negative or pN1 (mi) breast cancer | NR NR
Henry, 2009^139^ Oncotype DX (breast) Low | 29 Cohort | United States | I–II Node negative, ER+ | Median (range): 51 (31 to 74) 96.5%
Holt, 2013^140^ Oncotype DX (breast) Medium | 142 Uncontrolled trial | United Kingdom | T1 – T3 ER+, node negative invasive breast cancer or minimal node involvement | Median (range): 55 (34 – 72) 100%
Joh, 2011^141^ Oncotype DX (breast) Low | 95 patients’ records Survey participants: 4 surgical oncologists; 4 medical oncologists; 4 pathologists Pre-post-test design; Uncontrolled trial | United States | Early stage, ER-positive breast cancer | Median overall age of patients is NR Patients with RS<18: Median: 54 years; Mean (SD) 55.5 (1.1) Patients with RS 18–30: Median 51 years, Mean (SD) 53.4 (1.3) Patients with RS >30: Median 58.5, Mean (SD) 59.1 (3.3) 100%
Kamal, 2011^142^ Oncotype DX (breast) Medium | 31 Uncontrolled trial | United States | Early stage ER+, node negative | Median (range): 53 (42–82) NR
Klang, 2010^143^ Oncotype DX (breast) Low | 313 Cohort | Israel | NR | Mean (range): 57 (29–81) 99%
Lo, 2010^144^ Oncotype DX (breast) Low | 17 oncologists 89 patients Uncontrolled trial | United States | I–II ER+, node negative | Mean (range): 55 (35–77) 100%
Rayhanabad, 2012^145^ Oncotype DX (breast) Low | 58 Cohort | United States | T1–T2 Node-negative, ER+ | Mean (range): 54 (26–78)
Schneider, 2012^146^ Oncotype DX (breast) Medium | 89 Cohort | United States | ER+, node negative | NR 100%
Yamauchi, 2013^147^ Oncotype DX (breast) Medium | 124 patients 17 physicians Uncontrolled trial | Japan | Invasive early breast cancer ER+, HER2− 0 to 3 positive lymph nodes | Mean: 51.4 100%

a 100 were enrolled; 96 were analyzed; 2 did not have assay results and outcome data were missing for 2.

Abbreviations: ER = estrogen receptor; HER = Human Epidermal Growth Factor; HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu; HR = hazard ratio; N = number; NR = not reported; PR = progesterone receptor; RS = risk score; SD: standard deviation.

#### Results: Oncotype DX and Treatment Decisions

Across studies, the percentage of patients whose recommendation for treatment was changed by the Oncotype test result was generally around 30 percent, ranging from 14 percent to 40 percent. Although treatment decision changes were observed in both directions for individual patients, all studies consistently showed a pattern of a shift to less-intensive treatment recommendations (more patients moving from chemotherapy plus hormonal therapy to hormonal therapy alone than from hormonal therapy to combination therapy) as a result of including the Oncotype score in decisionmaking information (Table 38).

One cohort study139 also included a nested uncontrolled trial in which a panel of five experts provided treatment recommendations with and without the Oncotype score for patients included in the observational cohort; results were consistent with the other studies.

Table 38 Impact of test results on treatment decisions

Author, Year, Design, N, Test (Cancer), Risk of Bias | Decisions Based on Molecular Pathology Test Results Combined With Standard Prognostic Markers | Decisions Based on Standard Prognostic Markers Alone
Ademuyiwa, 2011^132^ Pre-post-test design an uncontrolled trial 276 Oncotype DX (breast) Medium | ODX score OR: 1.23, 95% CI 1.16 to 1.29, p<0.001 Overall change: 38% | 71/188 no CTX patients: recommended for CTX based on ODX blinded records review. 34/88 CTX patients; recommended for no CTX based on ODX blinded records review.
Albanell, 2011^133^ Uncontrolled trial 107 Oncotype DX (breast) Low | Overall change: 34 (32%; 95% CI 26% to 34%) CTX to no CTX: 22 (21%; 95% CI 19.6% to 21.6%) No CTX to CTX: 12 (11%; 95% CI 10.6% to 11.8%) In each group: No CTX to CTX: 12 of 68 (18%) CTX to no CTX: 22 of 39 (56%) CTX in each RS group: Total CTX: 29 of 107 (27%) Low RS: 2/62 (3%) Intermediate RS: 17/35 (49%) High RS: 10/10 (100%) | CTX: 39 (36%) No CTX: 68 (64%) CTX in each RS group: Low RS: 22 (35%) Intermediate RS: 9 (26%) High RS: 8 (80%)
Bargallo, 2012^134^ Uncontrolled trial 96 Oncotype DX (breast) Medium | Overall change: 14% Proportion recommended CTX decreased from 48% to 34% (p=0.024). Decrease by subgroups: 6% decrease in N0 patients, and 26% in N_mic_ and N1-3 patients. Net decrease in chemotherapy recommendations: 13/96 = 14% (95% CI 7%–22%). | HT: 50 (52%) CHT: 46 (48%)
Davidson, 2013^135^ Uncontrolled trial 150 Oncotype DX (breast) Medium | Overall change: 45 (30%) (95% CI: 22.8 to 38.0%) CTX to no CTX: 20% (95% CI 13.9 to 27.3%) No CTX to CTX: 10% (95% CI 5.7 to 16.0%) CTX in each RS group: Total CTX: 47 (31.3%) [percentage change overall=−10] Low RS: 0 [percentage change=−29] Intermediate RS: 13 [percentage change=−11] High RS: 34 [percentage change=+28] | CTX: 62 (41.3%) CTX in each RS group: Low RS: 20 Intermediate RS: 18 High RS: 24
De Boer, 2013^136^ Uncontrolled trial 151 Oncotype DX (breast) Medium | Node negative: Overall change: 24% HTX to CTX+HTX: 12/71 (17%) CTX+HTX to HTX: 12/30 (40%) Node positive: Overall change: 26% HTX to CTX+HTX: 1/13 (8%) CTX+HTX to HTX: 12/37 (32%) | Node negative: Treatment plan pre-RS HTX=71 (70%) CTX+HTX=30 (30%) Node positive: Treatment plan pre-RS HTX=13 (26%) CTX+HTX=37 (74%)
Eiermann, 2013^137^ Cohort 366 Oncotype DX (breast) Low | Overall change: 33% 95 CI (28.3, 38.1); CTX=HTX to HTX: 22% HTX to CTX+HTX: 11% Other: 1% Node negative overall change: 30% change 95% CI (24.6, 36.5) CTX+HTX to HTX: 18% HTX to CTX+HTX: 12% CTX+HTX to CTX: 1 patient Node positive: Overall change: 39% 95% CI (29.9, 47.8); CTX+HTX to HTX: 28% HTX to CTX+HTX: 9% Observation to HTX or CTX+HTX: 2% | CTX+HTX overall: 209 (57%) CTX+HTX node negative: 48% CTX+HTX node positive: 75%
Geffen, 2011^138^ Cohort 135 Oncotype DX (breast) Medium | Overall change: 34 (25.2%; 95% CI 17.9% to 32.5%) CTX to HTX: 24 (17.8%; 95% CI 11.3% to 24.2%) HTX to CTX: 10 (7.4%; 95% CI 2.9% to 11.8%) CTX in each risk group Low risk: 10% Intermediate risk: 55% High risk: 35% No CTX in each risk group Low risk: 72% Intermediate risk: 28% High risk: 0% | CTX: 63 (47%) No CTX: 72 (53%) CTX in each risk group: Low risk: 41% Intermediate risk: 41% High risk: 17% No CTX in each risk group Low risk: 57% Intermediate risk: 35% High risk: 8%
Henry, 2009^139^ Cohort 29 Oncotype DX (breast) Low | Treating physicians: Overall change: 9 (31%) CTX to no CTX: 7 of 13 patients (54%) No CTX to CTX: 2 of 16 (13%) Expert panel: Overall change: 7 (24%) CTX to no CTX: 5 of 12 patients (42%) No CTX to CTX: 2 of 17 (12%) | Treating physicians: CTX: 13 (45%) HTX: 16 (55%) Expert panel: CTX: 12 (41%) HTX: 17 (59%)
Holt, 2013^140^ Uncontrolled trial 142 Oncotype DX (breast) Medium | Overall change: 38 (26.76%) CTX + HT to HT: 26/57 (45.61%) HT to CTX+HT: 12/85 (14.12%) | Overall: CTX + HT: 57 (40.14%) HT: 85 (59.86%)
Joh, 2011^141^ Pre-post-test design and uncontrolled trial 95 patients’ records Survey participants: 4 surgical oncologists, 4 medical oncologists, 4 pathologists Oncotype DX (breast) Low | Overall change: 24.9% % overtreated: 69.0% +/− 6.9% (range 5.9 to 85.7) p=0.0322 (compared with treatment decisions made with standard prognostic markers alone) | % Over treated: 82.3% +/− 1.3% (range 75.5 to 89.0)
Kamal, 2011^142^ Uncontrolled trial 31 Oncotype DX (breast) Medium | Overall change: 19% of 31 cases changed 5 oncologists recommended chemotherapy in 10%–19% of 31 cases; 1 oncologist recommended chemotherapy in 58% of 31 cases Type of changes in chemotherapy recommendation (N=186 scenarios): No change, 151 (81.2%) CTX to no CTX: 20 (10.8%) No CTX to CTX: 15 (8.1%) Odds ratio of actual Oncotype DX RS changing chemotherapy recommendation: High vs. low: OR=82.650 (95% CI, 8.959 to 762.496) Intermediate vs. low: OR=6.463 (95% CI, 1.682 to 24.841) | 5 oncologists recommended chemotherapy in 16% to 23% of the 31 cases; 1 oncologist recommended chemotherapy in 52% of 31 cases
Klang, 2010^143^ Cohort 313 Oncotype DX (breast) Low | Overall change: 125 (40%) CTX to no CTX: 105 (34%) | CTX: 174 (56%)
Lo, 2010^144^ Uncontrolled trial 17 oncologists; 89 patients Oncotype DX (breast) Low | Overall change: 28 (31.5%) No CTX to no CTX: 40 (44.9%) No CTX to CTX: 3 (3.4%) CTX to no CTX: 20 (22.5%) CTX to CTX: 20 (22.5%) No CTX to equipoise: 3 (3.4%) CTX to equipoise: 2 (2.2%) Equipoise to equipoise: 1 (1.1%) HER2/neu-positive subset (N=6) CTX to no CTX: 1 (16.6%) CTX to CTX: 4 (66.7%) No CTX to no CTX: 1 (16.6%) (Note: equipoise is defined as equal options of either CTX, no CTX, or enrollment onto the TAILORx clinical trial, where patients would be randomly assigned between CTX followed by no CTX or no CTX alone) | CTX: 42 (47%), No CTX: 46 (51.7%) Either CTX or no CTX to one patient (1.1%)
Rayhanabad, 2012^145^ Cohort 58 Oncotype DX (breast) Low | Overall change: 15/58 patients (26%) 23 (40%) low risk by RS 30 (51%) intermediate risk by RS 5 (9%) high risk by RS ODX increased the number of patients classified as low risk by 12% No CTX to CTX: 2/16 CTX to No CTX: 13/42 | No CTX: 16 (28%) low risk by National Comprehensive Cancer Network CTX: 42 (72%) high risk by National Comprehensive Cancer Network
Schneider, 2012^146^ Cohort 89 Oncotype DX (breast) Medium | Overall change: 45% CTX to HT: 39% HT to CTX: 4.5% | CTX: 61% HT: 39%
Yamauchi, 2013^147^ Uncontrolled trial 124 patients 17 physicians Oncotype DX (breast) Medium | Change in treatment recommendations among all patients: 47/124 patients (38%) Change in treatment recommendations for N0 patients: 34/104 patients (33%) Change in treatment recommendations for N+ patients: 13/20 patients (65%) CHT to HT: 40/63 patients (63%) CHT to HT in N0 patients: 27/48 patients (56%) CHT to HT in N+ patients: 13/15 patients (87%) HT to CHT: 7/61 patients (11%) HT to CHT in N0 patients: 7/56 patients (13%) HT to CHT in N+ patients: 0 patients (0%) | CHT: 63/124 patients (51%) HT: 61/124 patients (49%)

Abbreviations: CI = confidence interval; CHT = chemohormonal therapy; CTX = chemotherapy; HER2/neu = Human Epidermal Growth Factor Receptor 2, also known as Neu; HT = hormonal therapy; HTX = hormone treatment; N = number; NR = not reported; ODX = original diagnosis; RS= risk score; TAILORx = Tailored treatment; vs. = versus.

#### Characteristics of Included Studies Assessing MammaPrint and Treatment Decisions

We included one cohort study regarding decisionmaking (Table 39). This study was performed entirely in the Netherlands and included 427 women with a median age of 48 years and with node-negative invasive breast cancers. None of the patients were over 65 years of age. In the cohort study, physicians’ treatment recommendations based on Dutch clinical guidelines were compared with recommendations based on the combination of clinical guidelines and the MammaPrint result.148

Table 39 Characteristics of included studies: MammaPrint and treatment decisions

Author, Year Test (Cancer Type) Risk of Bias | N Study Type | Country(ies) | Disease Stage(s) Other Tumor/Disease Characteristics | Overall Age (years) % Female
Bueno-de-Mesquita, 2007^148^ MammaPrint (breast) Low | 427 Pre-post-test design an uncontrolled trial | The Netherlands | T I–IIII Node negative | Mean (SD): 48 (7); Median (range) 49 (27 to 60) 100%

Abbreviations: N = number; SD: standard deviation.

#### Results: MammaPrint and Treatment Decisions

The addition of the MammaPrint test result increased the percentage of patients recommended to receive some form of adjuvant therapy (either hormonal therapy, chemotherapy, or both) from 48 to 62 percent. However, the greatest increase was among women moving from no therapy to hormonal therapy. One significant limitation of this study for application to the U.S. population is that Dutch treatment guidelines during the study period were unusually restrictive in terms of indications for breast cancer adjuvant therapy compared with more widely accepted guidelines in the United States; specifically, women with hormone-receptor positive breast cancers would be uniformly recommended to receive hormonal therapy under U.S. guidelines.

#### Characteristics of Included Studies Assessing Oncotype DX Colon and Treatment Decisions

We identified three eligible studies (Table 40). Two were conducted in the United States and one in Israel. One cross-sectional survey assessed the treatment decisions of 116 physicians;149 one uncontrolled trial assessed treatment decisions of 105 oncologists;150 and one cohort study examined treatment recommendations before assay results compared with actual treatment received after assay results for 269 patients.151 One study was rated as high RoB and two were rated as unclear RoB. Appendix C provides additional rationale for RoB ratings.

Table 40 Characteristics of included studies: Oncotype DX Colon and treatment decisions

Author, Year Test (Cancer Type) Risk of Bias | N Study Type | Country(ies) | Disease Stage(s) Other Tumor/Disease Characteristics | Overall Age (years) % Female
Brenner, 2013^151^ Oncotype DX (colorectal) High | 269 patients Cohort | Israel | II | NR (but reported 48% were at least 70 years old) NR
Cartwright, 2012^149^ Oncotype DX (colorectal) High | 116 physicians 92 patients Cross-sectional survey | United States | II | Mean (SD): 61.3 (11.8) NR
Srivastava, 2013^150^ Oncotype DX (colorectal) Unclear | 105 oncologists 141 patients Uncontrolled trial | United States | II | NR NR

Abbreviations: N = number; NR = not reported; SD = standard deviation.

#### Results: Oncotype DX Colon and Treatment Decisions

With no studies rated as low or medium RoB, we found no reliable data to inform conclusions about the impact of the Oncotype DX Colon test on treatment decisions.

### Key Question 4b Clinical Utility—Evidence that Modified Decisions Lead to Improved Outcomes

We found no eligible studies that addressed this question.

### Key Question 5 Harms Associated with Treatment Decisions that are Informed by Molecular Pathology Tests

We found no eligible studies that addressed this question.